# Disability Measures

## Basic Actions Difficulty or Complex Activity Limitation

Reported disability among adults 18–64 and 65 years of age and over was higher among those living below 200% of poverty compared with those in higher relative family income groups during 2000–2010.

Any basic actions difficulty or complex activity limitation—subsequently referred to as disability—is defined as a respondent report of one or more of the following: movement difficulty, emotional difficulty, sensory (seeing or hearing) difficulty, cognitive difficulty, self-care (ADL or IADL) limitation, social limitation, or work limitation (Table 54) (1).

In 2010, one-third of American adults reported a disability. About one-quarter of adults 18–64 years of age reported a disability, compared with three-fifths of adults 65 years of age and over.

In 2010, among adults 18–64 years of age, disability was almost twice as high among those living in poverty, 1.6 times as high for those with family income at 100%–199% of poverty, and 1.3 times as high for those with family income at 200%–399%, compared with those with income at 400% or more of the poverty level. Among older adults, disability was 1.5 times as high among those living below 200% of the poverty level and 1.3 times as high for those with family income at 200%–399%, compared with the highest relative family income group.

Disability may be either a cause or a consequence of lower family income. It may lead to lower income due to lower earning potential, reduced productivity, and less access to employment opportunities (2–4). Family income level may also affect the prevalence of disability through employment and education opportunities, living and environmental conditions, and access to health care, preventive services, and accommodations.

Figure 36 Basic actions difficulty or complex activity limitation among adults 18 years of age and over, by age and percent of poverty level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig36

NOTE: See data table for Figure 36.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 36 consists of two line graphs, one for adults 18 to 64 years of age and one for adults 65 years and over, showing basic actions difficulty or complex activity limitation, by percent of poverty level, for 2000 through 2010.

## References

1 Altman B, Bernstein A. Disability and health in the United States, 2001–2005. Hyattsville, MD. NCHS. 2008. Available from: http://www.cdc.gov/nchs/data/misc/disability2001-2005.pdf.
2 Isaacs SL, Schroeder SA. Class—The ignored determinant of the nation’s health. N Engl J Med. 2004;351(11):1137-42. [pmid: 15356313].
3 Brault MW. Americans with disabilities: 2005. U.S. Census Bureau, Current Population Reports, P70–117. Washington, DC. U.S. Government Printing Office. 2008. Available from: http://www.census.gov/prod/2008pubs/p70-117.pdf.
4 Minkler M, Fuller-Thomson E, Guralnik JM. Gradient of disability across the socioeconomic spectrum in the United States. N Engl J Med. 2006;355(7):695-703. [pmid: 16914705].