# Children

Background

Morbidity

Health Risk Factors

Prevention

Health Insurance

Utilization and Access