# Background

## Child Poverty

The percentage of children living in poverty declined in the 1990s but increased in the 2000s; the percentage living in poverty varied by racial and ethnic group throughout this period.

Growing up in poverty raises children’s risks for school failure, poor health, and teen pregnancy and childbearing (1–3). In all racial and ethnic groups, children are more likely to be poor than adults (Figures 22 and 31). In 2010, 16.4 million children lived in poverty (4).

Figure 22 Children under 18 years of age, by percent of poverty level and race and Hispanic origin: United States, 1990–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig22

NOTE: See data table for Figure 22.

SOURCE: U.S. Census Bureau. See Appendix I, Current Population Survey (CPS).

Figure 22 consists of a line graph and four pie charts showing children under 18 years of age, by percent of poverty level and race and Hispanic origin, for 1990 through 2010.

Between 1990 and 2000, the percentage of children under 18 years of age living in poverty declined from 21% to 16% and then rose to 22% in 2010. During the 1990s, the percentage of children living in poverty declined among black, Hispanic, Asian, and non-Hispanic white children, but rates for all groups were stable or rose in the 2000s. Black and Hispanic children had higher poverty rates than Asian and non-Hispanic white children between 1990 and 2010.

The percentage of children in the four relative family income groups shown in many of the subsequent charts in this Special Feature differed by race and ethnicity. In 2010, 39% of black children and 35% of Hispanic children were poor, compared with 14% of Asian children and 12% of non-Hispanic white children. Two-thirds of black children and Hispanic children lived below 200% of the poverty level, as did one-third of Asian children and 29% of non-Hispanic white children. Eleven percent of black children and Hispanic children lived in families with an income at 400% or more of the poverty level, compared with 40% of Asian children and 37% of non-Hispanic white children.

## References

1 Brooks-Gunn J, Duncan GJ. The effects of poverty on children. Future Child. 1997;7(2):55-71. [pmid: 9299837].
2 Wood D. Effect of child and family poverty on child health in the United States. Pediatrics. 2003;112(3 pt 2):707-11. [pmid: 12949326].
3 Chen E, Martin AD, Matthews KA. Socioeconomic status and health: Do gradients differ within childhood and adolescence?. Soc Sci Med. 2006;62(9):2161-70. [pmid: 16213644].
4 DeNavas-Walt C, Proctor BD, Smith JC. Income, poverty, and health insurance coverage in the United States: 2010. U.S. Census Bureau, Current Population Reports, P60–239. Washington, DC. U.S. Government Printing Office. 2011. Available from: http://www.census.gov/prod/2011pubs/p60-239.pdf.