# Adults

Background

Mortality

Morbidity

Disability Measures

Health Risk Factors

Prevention

Health Insurance

Access to Care