# Access to Care

## Delay or Nonreceipt of Medical Care in the Past 12 Months Due to Cost

Adults 18–64 years of age with family income below 200% of the poverty level were more likely than those with higher relative family income to delay seeking or not receive needed medical care due to cost for all racial and ethnic groups in 2009–2010.

Foregoing or delaying needed medical care can have serious health effects (1). Between 2000 and 2010, the percentage of adults 18–64 years of age who did not get, or delayed seeking, needed medical care during the past 12 months due to cost increased in all relative family income groups. During this period, the percentage with unmet need for medical care decreased as relative family income increased from below 200% of the poverty level to 400% or more of the poverty level. Unmet need for medical care was equally likely among those below poverty and for those with a family income at 100%–199% of the poverty level.

In 2009–2010, unmet need for medical care decreased as relative family income increased for all racial and ethnic groups. The difference in the percentage with unmet need between the highest and lowest relative income groups was 20 percentage points for non-Hispanic white adults, 15 percentage points for non-Hispanic black adults, and 13 percentage points for Hispanic adults and for Asian adults.

Health insurance is a major determinant of access to needed medical services, but does not guarantee such access because of cost-sharing, noncoverage of some services, and the existence of nonfinancial barriers to access to care (2). Between 2000 and 2010, uninsured adults were much more likely than insured adults to have delayed seeking or not received needed medical care due to cost (Table 79).

Figure 41 Delay or nonreceipt of needed medical care in the past 12 months due to cost among adults 18–64 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig41

NOTE: See data table for Figure 41.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 41 consists of a line graph and a bar chart showing adults 18 to 64 years of age who did not get or delayed seeking medical care in the past 12 months due to cost, by percent of poverty level and race and Hispanic origin, for 2000 through 2010.

## References

1 Cunningham PJ, Felland LE. Falling behind: Americans’ access to medical care deteriorates, 2003–2007. Track Rep. 2008;19:1-5. Available from: http://hschange.org/CONTENT/993/. [pmid: 18610514].
2 NCHS. Health, United States, 2007: With chartbook on trends in the health of Americans. Hyattsville, MD. 2007. Available from: http://www.cdc.gov/nchs/data/hus/hus07.pdf.