# Chartbook: Figures 22–41

Introduction

Children

Adults

Technical Notes

Data Tables for Special Feature: Figures 22–41