# Personal Health Care Expenditures

## Source of Funds

Out-of-pocket spending for personal health care expenditures grew less rapidly than Medicare, Medicaid, and private insurance spending from 1999 to 2009.

Between 1999 and 2009, total personal health care expenditures grew from $1.1 trillion to $2.1 trillion. During this period, the average annual growth in Medicare expenditures was 9%, for Medicaid and private insurance 7%, and for out-of-pocket spending 5%. In 2009, 34% of personal health care expenditures were paid by private health insurance, 23% by Medicare, 17% by Medicaid, 14% out of pocket, and less than 1% by the Children’s Health Insurance Program (CHIP).

Figure 20 Personal health care expenditures, by source of funds: United States, 1999–2009

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig20

SOURCE: CDC/NCHS, Health, United States, 2011, Table 129. Data from the Centers for Medicare & Medicaid Services, National Health Expenditure Accounts (NHEA).

Figure 20 is a line graph showing trends in personal health care expenditures, by source of funds, for 1999 through 2009

## Type of Expenditure

Between 1999 and 2009, spending for prescription drugs and home health care grew rapidly.

Between 1999 and 2009, the average annual growth was 9% for prescription drugs, 8% for home health care, 7% for hospital care, 6% for physician and clinical services and dental services, and 5% for nursing care facilities and continuing care retirement communities. In 2009, 36% of personal health care expenditures were spent on hospital care, 24% on physician care, 12% on prescription drugs, and 7% on nursing care and continuing care retirement communities.

Figure 21 Personal health care expenditures, by type of expenditure: United States, 1999–2009

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig21

SOURCE: CDC/NCHS, Health, United States, 2011, Table 129. Data from the Centers for Medicare & Medicaid Services, National Health Expenditure Accounts (NHEA).

Figure 21 is a line graph showing trends in personal health care expenditures, by type of expenditure, for 1999 through 2009.