# References for Figures 1–21

1 Miniño AM, Murphy SL, Xu JQ, Kochanek KD. Deaths: Final data for 2008. National vital statistics reports. Hyattsville, MD. NCHS. 2011;59(10). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr59/nvsr59_10.pdf.
2 CDC/NCHS. Compressed mortality file 1999–2008. CDC WONDER online database, compiled from Compressed Mortality File 1999–2008. Forthcoming. 2012. Available from: http://wonder.cdc.gov/cmf-icd10.html.
3 Altman B, Bernstein A. Disability and health in the United States, 2001–2005. Hyattsville, MD. NCHS. 2008. Available from: http://www.cdc.gov/nchs/data/misc/disability2001-2005.pdf.
4 The health consequences of smoking: A report of the Surgeon General. National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. Washington, DC. U.S. Government Printing Office. 2004. Available from: http://www.cdc.gov/tobacco/data_statistics/sgr/sgr_2004/index.htm.
5 National High Blood Pressure Education Program. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: Complete report. NIH pub no 04–5230. Bethesda, MD. National Heart, Lung, and Blood Institute, National Institutes of Health. 2004. Available from: http://www.nhlbi.nih.gov/guidelines/hypertension/jnc7full.htm.
6 Dietz WH. Health consequences of obesity in youth: Childhood predictors of adult disease. Pediatrics. 1998;101(3 pt 2):518-25. [pmid: 12224658].
7 Ogden CL, Carroll MD, Curtin LR, Lamb MM, Flegal KM. Prevalence of high body mass index in U.S. children and adolescents, 2007–2008. JAMA. 2010;303(3):242-9. [pmid: 20071470].
8 National Heart, Lung, and Blood Institute and National Institute of Diabetes and Digestive and Kidney Diseases. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: The evidence report. NIH pub no 98–4083. Bethesda, MD. National Institutes of Health. 1998. Available from: http://www.nhlbi.nih.gov/guidelines/obesity/ob_gdlns.pdf.
9 National Task Force on the Prevention and Treatment of Obesity. Overweight, obesity, and health risk. Arch Intern Med. 2000;160(7):898-904. [pmid: 10761953].
10 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA. 2005;293(15):1861-7. [pmid: 15840860].
11 CDC. Recommendations of the Advisory Committee on Immunization Practices (ACIP): General recommendations on immunization. MMWR. 2011;60(RR–2):1-60. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/rr6002a1.htm?s_cid=rr6002a1_e.
12 CDC. Experiences with obtaining influenza vaccination among persons in priority groups during a vaccine shortage—United States, October–November, 2004. MMWR. 2004;53(49):1153-5. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5349a2.htm. [pmid: 15614228].
13 Jemal A, Siegel R, Xu J, Ward E. Cancer statistics, 2010. CA Cancer J Clin. 2010;60(5):277-300. Available from: http://onlinelibrary.wiley.com/doi/10.3322/caac.20073/pdf. [pmid: 20610543].
14 U.S. Preventive Services Task Force. Screening for breast cancer. Rockville, MD. USPSTF Program Office. 2009. Available from: http://www.uspreventiveservicestaskforce.org/uspstf/uspsbrca.htm.
15 American Cancer Society responds to changes to USPSTF mammography guidelines [press release]. Atlanta, GA. 2009. November. 16. Available from: http://pressroom.cancer.org/index.php?s=43&item=201.
16 Kaiser Commission on Medicaid and the Uninsured. The uninsured and the difference health insurance makes. Kaiser Family Foundation. 2010. Available from: http://www.kff.org/uninsured/upload/1420-12.pdf.
17 Centers for Medicare & Medicaid Services. Children’s Health Insurance Program (CHIP). Available from: http://www.cms.hhs.gov/NationalCHIPPolicy.
18 Garcia TC, Bernstein AB, Bush MA. Emergency department visitors and visits: Who used the emergency room in 2007?. NCHS data brief, no 38. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/databriefs/db38.pdf.
19 Diamant AL, Hays RD, Morales LS, Ford W, Clames D, Asch S, et al. Delays and unmet need for health care among adult primary care patients in a restructured urban public health system. Am J Public Health. 2004;94(5):783-9. [pmid: 15117701].
20 Baker DW, Shapiro MF, Schur CL. Health insurance and access to care for symptomatic conditions. Arch Intern Med. 2000;160(9):1269-74. [pmid: 10809029].