# Natality

## Teenage Birth Rates

From 1998 to 2008, teenage birth rates declined among most racial and ethnic groups.

In 2008, 3% of births were to teenagers under 18 years of age and 7% were to mothers 18–19 years of age (Table 6). Between 1998 and 2008, birth rates declined 27% for teenagers 15–17 years of age and 13% for those 18–19 years of age (Table 3). Since 1998, birth rates have decreased 21% for Hispanic teenagers 15–17 years of age and 39% for non-Hispanic black teenagers 15–17 years of age. During this period, birth rates for 18–19 year olds decreased 18% for non-Hispanic black teenagers and were stable for older Hispanic teenagers.

Figure 5 Teenage childbearing, by maternal age and race and Hispanic origin: United States, 1998–2008

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig05

SOURCE: CDC/NCHS, Health, United States, 2011, Table 3. Data from the National Vital Statistics System (NVSS).

Figure 5 consists of two line graphs, one for mothers 15 to 17 years of age and one for mothers 18 to 19 years of age, showing teenage childbearing, by race and Hispanic origin, for 1998 through 2008.