# Mortality

## Life Expectancy at Birth

The gap in life expectancy at birth between white persons and black persons persists but has narrowed since 1990.

Life expectancy is a measure often used to gauge the overall health of a population. From 1980 to 2008, life expectancy at birth in the United States increased from 70 years to 76 years for males and from 77 years to 81 years for females. Racial disparities in life expectancy at birth persisted for both males and females in 2008 but had narrowed since 1990. In 2008, Hispanic males and females had longer life expectancy at birth than non-Hispanic white or non-Hispanic black males and females.

Figure 1 Life expectancy at birth, by race and sex and Hispanic origin: United States, 1980–2008

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig01

SOURCE: CDC/NCHS, Health, United States, 2011, Table 22. Data from the National Vital Statistics System (NVSS).

Figure 1 consists of a line graph showing trends in life expectancy at birth, by race and sex, for 1980 through 2008, and a bar chart showing life expectancy in 2008 by sex and race and Hispanic origin.

## Infant Mortality

Infant and neonatal mortality rates declined between 1998 and 2008.

The infant mortality rate is the risk of death during the first year of life. The 2008 infant mortality rate of 6.61 per 1,000 live births was 8% lower than in 1998. During the same period, the neonatal mortality rate (death rate among infants under 28 days) decreased 11%, to 4.29 per 1,000 live births, and the postneonatal mortality rate (death rate among infants 28 days through 11 months) remained stable.

Figure 2 Infant, neonatal, and postneonatal mortality rates: United States, 1998–2008

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig02

SOURCE: CDC/NCHS, Health, United States, 2011, Table 17 and reference 1. Data from the National Vital Statistics System (NVSS).

Figure 2 is a line graph showing infant, neonatal, and postneonatal mortality rates for 1998 through 2008.

## Selected Causes of Death

Between 1998 and 2008, the age-adjusted death rate decreased 16% among males and 11% among females.

During this 10-year period, age-adjusted death rates among males for stroke declined 33%, heart disease declined 32%, cancer declined 15%, and unintentional injuries increased 10%. Among females, age-adjusted death rates for heart disease declined 32%, stroke declined 31%, cancer declined 11%, and unintentional injuries increased 15%. In 2008, age-adjusted death rates were higher for males than females for heart disease, cancer, chronic lower respiratory diseases, diabetes, and unintentional injuries, were similar for stroke, and were higher among females than males for Alzheimer’s disease.

Figure 3 Death rates for selected causes of death for all ages, by sex: United States, 1998–2008

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig03

NOTE: Starting with 1999 data, cause of death is coded according to the International Classification of Diseases, 10th Revision (ICD–10).

SOURCE: CDC/NCHS, Health, United States, 2011, Table 24. Data from the National Vital Statistics System (NVSS).

Figure 3 consists of two line graphs, one for males and one for females, showing age-adjusted death rates for selected causes of death for all ages, for 1998 through 2008.

## Motor Vehicle-related Death Rates

Between 1998 and 2008, motor vehicle-related death rates declined among males and females 15–19 years of age while fluctuating among males and females 20–24 years of age.

Motor vehicle-related deaths are a significant cause of preventable death, accounting for about 40,000 deaths in the United States in 2008 across all ages (2). Motor vehicle-related death rates are higher for males and females 15–24 years of age than for most other age groups (Table 37). For males 15–19 years of age, motor vehicle-related death rates declined 30% from 1998 to 2008, and for females 15–19 years of age, motor-vehicle death rates declined 33% during this period. Motor vehicle-related death rates for males and females 20–24 years of age fluctuated during this time.

Figure 4 Motor vehicle-related death rates among persons 15–24 years of age, by sex and age: United States, 1998–2008

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig04

SOURCE: CDC/NCHS, Health, United States, 2011, Table 37. Data from the National Vital Statistics System (NVSS).

Figure 4 is a line graph showing motor vehicle-related death rates among persons 15 to 24 years of age, by sex and age group, for 1998 through 2008.