# Morbidity

## Heart Disease Prevalence

From 1999–2000 to 2009–2010, heart disease prevalence remained stable among women in all age groups and among men 45–74 years of age.

Heart disease is the leading cause of death in the United States, accounting for about 617,000 deaths in 2008 (Table 26). Between 1999–2000 and 2009–2010, the prevalence of lifetime respondent-reported heart disease among adults 18–54 years of age was similar for men and women. Among adults 55 years of age and over, heart disease prevalence was higher for men than for women. Among adult women in all age groups, and among men 45–74 years of age, prevalence remained steady from 1999–2000 to 2009–2010. Among men 75 years of age and over, prevalence rose from 39% in 1999–2000 to 45% in 2009–2010.

Figure 6 Respondent-reported lifetime heart disease prevalence among adults 18 years of age and over, by sex and age: United States, 1999–2000 through 2009–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig06

SOURCE: CDC/NCHS, Health, United States, 2011, Table 49. Data from the National Health Interview Survey (NHIS).

Figure 6 consists of two line graphs, one for men and one for women, showing respondent-reported lifetime heart disease prevalence among adults 18 years of age and over, by age group, for 1999 to 2000 through 2009 to 2010.