# Health Risk Factors

## Current Cigarette Smoking

In 2010, 19% of high school seniors, 22% of men, and 17% of women were current cigarette smokers.

Smoking is associated with an increased risk of heart disease, stroke, lung and other types of cancers, and chronic lung diseases (4). Between 2000 and 2010, cigarette smoking among students in grade 12 decreased from 33% to 22% for male students and from 30% to 16% for female students. During this period, the percentage of adults who smoked cigarettes declined for men and women 18–44 and 45–64 years of age, while remaining stable for adults 65 years of age and over.

Figure 8 Current cigarette smoking among high school seniors and adults 18 years of age and over, by sex and age: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig08

SOURCE: CDC/NCHS, Health, United States, 2011, Tables 60 and 65. Data from the National Health Interview Survey (NHIS) and the Monitoring the Future (MTF) Study.

Figure 8 consists of two line graphs, one for males and one for females, showing current cigarette smoking among high school seniors and adults 18 years of age and over, by age group, for 2000 through 2010.

## Uncontrolled High Blood Pressure

Although control of high blood pressure has improved since 1988–1994, nearly one-half of adults with hypertension had uncontrolled high blood pressure in 2007–2010.

Hypertension increases the risk for cardiovascular disease, heart attack, and stroke (5). Between 1988–1994 and 2007–2010, the prevalence of uncontrolled high blood pressure (defined as an average systolic blood pressure of 140 mm Hg or higher, or an average diastolic pressure of 90 mm Hg or higher, among those with hypertension) declined for all age groups of men and women. However, in 2007–2010, nearly one-half of adults with hypertension continued to have uncontrolled high blood pressure.

Figure 9 Uncontrolled high blood pressure among adults 20 years of age and over for persons with hypertension, by sex and age: United States, 1988–1994, 1999–2002, and 2007–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig09

SOURCE: CDC/NCHS, Health, United States, 2011, Table 70. Data from the National Health and Nutrition Examination Survey (NHANES).

Figure 9 consists of two line graphs, one for men and one for women, showing uncontrolled high blood pressure among adults 20 years of age and over for persons with hypertension, by age group, for 1988 through 1994, 1999 through 2002, and 2007 through 2010.

## Obesity Among Children

In 2009–2010, almost one in five children older than 5 years of age was obese.

Excess body weight in children is associated with excess morbidity in childhood and adulthood (6). The percentage of children 2–5 years of age who were obese rose from 7% in 1988–1994 to 10% in 1999–2000 and has held steady since that time (7). The prevalence of obesity among 6–11 year olds increased from 11% in 1988–1994 to 15% in 1999–2000 and has not increased significantly since then. Among adolescents 12–19 years of age, the prevalence of obesity rose from 11% in 1988–1994 to 15% in 1999–2000 and has not increased significantly since then.

Figure 10 Obesity among children, by age: United States, 1988–1994 through 2009–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig10

SOURCE: CDC/NCHS, Health, United States, 2011, Table 69. Data from the National Health and Nutrition Examination Survey (NHANES).

Figure 10 is a line graph showing trends in obesity among children, by age group, for 1988 to 1994 through 2009 to 2010.

## Overweight and Obesity Among Adults

In 2007–2010, 20% of adults had Grade 1 obesity, 9% had Grade 2 obesity, and 6% had Grade 3 obesity.

Excess body weight is correlated with excess morbidity and mortality (8,9). In particular, Grade 2 or higher obesity [a body mass index (BMI) of 35 or higher] significantly increases the risk of death (10). Between 1988–1994 and 2007–2010, the percentage of men and women who were overweight but not obese was stable while the percentage with obesity increased. During this period, the percentage with Grade 1 obesity (BMI greater than or equal to 30 but less than 35) increased more for men than for women. The percentage with Grade 2 obesity (BMI greater than or equal to 35 but less than 40) and Grade 3 obesity (BMI of 40 or higher) also increased among men and women during this period.

Figure 11 Overweight and obesity among adults 20 years of age and over, by sex: United States, 1988–1994, 1999–2002, and 2007–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig11

SOURCE: CDC/NCHS, Health, United States, 2011, Table 74. Data from the National Health and Nutrition Examination Survey (NHANES).

Figure 11 consists of two area graphs, one for men and one for women, showing overweight and grade 1, grade 2, and grade 3 obesity among adults 20 years of age and over, for 1988 to 1994 through 2007 to 2010.