# Health Insurance

## Coverage Among Children

Between 2000 and 2010, the percentage of children with private health insurance coverage declined while the percentage with Medicaid coverage increased at a faster rate, resulting in a decline in the percentage of children who were uninsured.

Health insurance is a major determinant of access to care (16). Between 2000 and 2010, the percentage of children under 18 years of age with private health insurance declined from 67% to 54%. During the same period, Medicaid coverage [a category that includes the Children’s Health Insurance Program (CHIP) (17)] increased from 20% to 36%. This led to a decline in the percentage of children who were uninsured, from 13% in 2000 to 8% in 2010.

Figure 14 Health insurance coverage among children under 18 years of age, by type of coverage: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig14

SOURCE: CDC/NCHS, Health, United States, 2011, Tables 138, 140, and 141. Data from the National Health Interview Survey (NHIS).

Figure 14 is a line graph showing trends in health insurance coverage among children under 18 years of age, by type of coverage, for 2000 through 2010.

## Coverage Among Adults 18–64 Years of Age

Between 2000 and 2010, the percentage of adults 18–64 years of age with private health insurance coverage decreased while the percentage uninsured increased.

Health insurance is a major determinant of access to health care. Among adults 18–44 years of age, the percentage with private coverage declined from 71% in 2000 to 60% in 2010 while Medicaid coverage increased from 6% to 11%. The percentage of persons 18–44 years of age who were uninsured increased from 22% to 27% during the same period. Similarly between 2000 and 2010, the percentage of adults 45–64 years of age with private coverage declined from 79% to 71%; the percentage with Medicaid coverage increased from 5% to 7%; and the percentage uninsured increased from 13% to 16%.

Figure 15 Health insurance coverage among adults 18–64 years of age, by age and type of coverage: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig15

SOURCE: CDC/NCHS, Health, United States, 2011, Tables 138, 140, and 141. Data from the National Health Interview Survey (NHIS).

Figure 15 consists of two line graphs showing health insurance coverage among adults 18 to 44 years of age and 45 to 64 years of age, by type of coverage, for 2000 through 2010.