# Health Care Resources

## Patient Care Physicians per Population

The number of patient care physicians per 10,000 population in the United States in 2009 ranged from a high of 40 in Massachusetts to a low of 17 in Idaho and Mississippi.

On average, there were 25 patient care physicians per 10,000 population in the United States in 2009. The New England states, Mid-Atlantic states, District of Columbia, Maryland, Hawaii, and Minnesota were in the highest quartile (27 or more patient care physicians per 10,000 population). States in the lowest quartile (17–21 patient care physicians per 10,000 population) included parts of the South and some of the Mountain states, along with Iowa and Indiana.

Figure 19 Patient care physicians per 10,000 population, by state: United States, 2009

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig19

SOURCE: CDC/NCHS, Health, United States, 2011, Table 109. Data from the American Medical Association (AMA) and the American Osteopathic Association (AOA).

Figure 19 is a map of the United States showing patient care physicians per 10,000 population, by state, for 2009.