# Disability Measures

## Basic Actions Difficulty or Complex Activity Limitation

The percentages of the noninstitutionalized population with each of two measures of disability—basic actions difficulty or complex activity limitation—were stable from 2000 to 2010.

Two constructs for defining and measuring disability status are basic actions difficulty and complex activity limitation (3). Basic actions difficulty captures limitations in movement, emotional, sensory, or cognitive functioning associated with a health problem. Complex activity limitation is the inability to function successfully in certain social roles, such as working, maintaining a household, living independently, or participating in community activities. Between 2000 and 2010, the prevalence of each measure was generally higher for women than men in the same age group, and higher for adults 65 years of age and over than for those 18–64 years of age.

Figure 7 Basic actions difficulty or complex activity limitation among adults 18 years of age and over, by sex and age: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig07

SOURCE: CDC/NCHS, Health, United States, 2011, Table 54. Data from the National Health Interview Survey (NHIS).

Figure 7 consists of two line graphs, one for men and one for women, showing basic actions difficulty or complex activity limitation among adults 18 years of age and over, by age group, for 2000 through 2010.