# Chartbook: Figures 1–21

Mortality

Natality

Morbidity

Disability Measures

Health Risk Factors

Prevention

Health Insurance

Utilization and Access

Health Care Resources

Personal Health Care Expenditures

References for Figures 1–21