# At a Glance Table

## Health, United States, 2011: At a Glance

| Value (year) | | | Health, United States, 2011 Figure/Table no.
Life Expectancy and Mortality
Life Expectancy in years | | | | Figure 1/Table 22
At birth | 76.8 (2000) | 77.9 (2007) | 78.5 (2009)
At 65 years | 17.6 (2000) | 18.6 (2007) | 19.2 (2009)
Infant deaths per 1,000 live births | | | | Figure 2/Table 17
All infants | 6.91 (2000) | 6.75 (2007) | 6.61 (2008)
Deaths per 100,000 population, age-adjusted | | | | Table 24
All causes | 869.0 (2000) | 760.2 (2007) | 758.3 (2008)
Heart disease | 257.6 (2000) | 190.9 (2007) | 186.5 (2008)
Cancer | 199.6 (2000) | 178.4 (2007) | 175.3 (2008)
Stroke | 60.9 (2000) | 42.2 (2007) | 40.7 (2008)
Chronic lower respiratory diseases | 44.2 (2000) | 40.8 (2007) | 44.0 (2008)
Unintentional injuries | 34.9 (2000) | 40.0 (2007) | 38.8 (2008)
Motor-vehicle | 15.4 (2000) | 14.4 (2007) | 12.9 (2008)
Diabetes | 25.0 (2000) | 22.5 (2007) | 21.8 (2008)
Morbidity and Risk Factors
Fair or poor health, percent | | | | Table 56
All ages | 8.9 (2000) | 9.9 (2009) | 10.1 (2010)
65 years and over | 26.9 (2000) | 24.0 (2009) | 24.4 (2010)
Heart disease, percent | | | | Table 49
18 years and over | 10.9 (1999–2000) | 11.6 (2007–2008) | 11.8 (2009–2010)
65 years and over | 29.6 (1999–2000) | 31.8 (2007–2008) | 30.4 (2009–2010)
Cancer (ever had), percent | | | | Table 49
18 years and over | 4.9 (1999–2000) | 5.8 (2007–2008) | 6.3 (2009–2010)
65 years and over | 15.2 (1999–2000) | 17.0 (2007–2008) | 18.1 (2009–2010)
Hypertension,^1^ percent | | | | Table 69
20 years and over | 28.9 (1999–2000) | 32.6 (2007–2008) | 31.9 (2009–2010)
High serum total cholesterol,^2^ percent | | | | Table 69
20 years and over | 17.7 (1999–2000) | 14.6 (2007–2008) | 13.6 (2009–2010)
Obese, percent | | | | Figures 10 and 11/Table 69
Obese,^3^ 20 years and over | 30.3 (1999–2000) | 33.9 (2007–2008) | 35.9 (2009–2010)
Obese (BMI at or above sex- and age-specific 95th percentile):
2–5 years | 10.3 (1999–2000) | 10.1 (2007–2008) | 12.1 (2009–2010)
6–11 years | 15.1 (1999–2000) | 19.6 (2007–2008) | 18.0 (2009–2010)
12–19 years | 14.8 (1999–2000) | 18.1 (2007–2008) | 18.4 (2009–2010)
Cigarette smoking, percent | | | | Figure 8/Table 60
18 years and over | 23.2 (2000) | 20.6 (2009) | 19.3 (2010)
Aerobic activity and muscle strengthening,^4^ percent | | | | Table 73
18 years and over | 15.1 (2000) | 18.8 (2009) | 20.4 (2010)
Health Care Utilization
No health care visit in past 12 months, percent | | | | Table 83
Under 18 years | 12.3 (2000) | 9.1 (2009) | 8.1 (2010)
18–44 years | 23.4 (2000) | 22.6 (2009) | 24.2 (2010)
45–64 years | 14.9 (2000) | 15.3 (2009) | 14.8 (2010)
65 years and over | 7.4 (2000) | 4.7 (2009) | 5.3 (2010)
Emergency room visit in past 12 months, percent | | | | Tables 93 and 94
Under 18 years | 20.3 (2000) | 20.8 (2009) | 22.1 (2010)
18–44 years | 20.5 (2000) | 22.0 (2009) | 22.0 (2010)
45–64 years | 17.6 (2000) | 18.4 (2009) | 19.2 (2010)
65 years and over | 23.7 (2000) | 24.9 (2009) | 23.7 (2010)
Dental visit in past year, percent | | | | Table 98
2–17 years | 74.1 (2000) | 78.4 (2009) | 78.9 (2010)
18–64 years | 65.1 (2000) | 62.0 (2009) | 61.1 (2010)
65 years and over | 56.6 (2000) | 59.6 (2009) | 57.7 (2010)
Prescription drug in past 30 days, percent | | | | Table 99
Under 18 years | 23.9 (2001–2004) | --- | 25.3 (2005–2008)
18–44 years | 37.7 (2001–2004) | --- | 37.8 (2005–2008)
45–64 years | 66.2 (2001–2004) | --- | 64.8 (2005–2008)
65 years and over | 87.3 (2001–2004) | --- | 90.1 (2005–2008)
Hospitalization in past year, percent | | | | Table 102
18–44 years | 7.0 (2000) | 6.7 (2009) | 6.3 (2010)
45–64 years | 8.4 (2000) | 8.5 (2009) | 8.3 (2010)
65 years and over | 18.2 (2000) | 17.1 (2009) | 16.1 (2010)
Health Insurance and Access to Care
Uninsured, percent | | | | Figures 14 and 15/Table 141
Under 65 years | 17.0 (2000) | 17.5 (2009) | 18.2 (2010)
Under 18 years | 12.6 (2000) | 8.2 (2009) | 7.8 (2010)
18–44 years | 22.4 (2000) | 25.9 (2009) | 27.1 (2010)
45–64 years | 12.6 (2000) | 14.6 (2009) | 15.7 (2010)
Delayed or did not receive needed medical care in past 12 months due to cost, percent | | | | Figure 18/Table 79
Under 18 years | 4.6 (2000) | 5.2 (2009) | 4.4 (2010)
18–44 years | 9.5 (2000) | 15.1 (2009) | 14.5 (2010)
45–64 years | 8.8 (2000) | 15.1 (2009) | 14.9 (2010)
65 years and over | 4.5 (2000) | 5.1 (2009) | 5.0 (2010)
Health Care Resources
Patient care physicians per 10,000 population | | | | Figure 19/Table 109
United States | 22.7 (2000) | 25.7 (2008) | 25.4 (2009)
Highest state | 34.4 (MA) (2000) | 39.7 (MA) (2008) | 39.6 (MA) (2009)
Lowest state | 14.4 ( I D) (2000) | 17.0 ( I D) (2008) | 17.3 (MS) (2009)
Community hospital beds per 1,000 population | | | | Table 118
United States | 2.9 (2000) | --- | 2.6 (2009)
Highest state | 6.0 (ND) (2000) | --- | 5.2 (ND) (2009)
Lowest state | 1.9 (NM,NV,OR,UT, WA) (2000) | --- | 1.7 (OR,WA) (2009)
Expenditures
Personal health care expenditures, dollars | | | | Figure 21/Table 129
Total in trillions | $1.2 (2000) | $2.0 (2008) | $2.1 (2009)
Per capita | $4,122 (2000) | $6,552 (2008) | $6,797 (2009)

--- Data not available.

1 Having measured high blood pressure (systolic pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg) and/or taking antihypertensive medication.

2 Having high serum total cholesterol of 240 mg/dl or greater.

3 Obesity is a body mass index (BMI) greater than or equal to 30. Height and weight are measured.

4 Meeting 2008 federal guidelines for aerobic activity and muscle strengthening.

NOTES: Some estimates are from the Excel spreadsheet version of the cited table and are not shown in the PDF version or in the printed version. For more information, data sources, notes, and the Excel version of the spreadsheet, see the complete report, Health, United States, 2011, available from: http://www.cdc.gov/nchs/hus.htm.