# Additional Data Years Available

For Trend Tables spanning long periods, only selected data years are shown, to highlight major trends. Additional years of data for some of the Trend Tables are available in electronic spreadsheet form on the Health, United States, 2011, website at: http://www.cdc.gov/nchs/hus.htm. Standard errors are included in the spreadsheet files for tables that are based on the National Health Interview Survey, the National Health and Nutrition Examination Survey, and the National Survey of Family Growth.

Table number | Table topic | Additional data years available
1 | Resident population | 2001–2006
2 | Poverty | 1986–1989, 1991–1994, 1996–1999, 2001–2003, 2005–2007
3 | Fertility rates and birth rates | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006
4 | Live births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2006
6 | Teenage childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006
7 | Nonmarital childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004
9 | Low birthweight | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006
12 | Abortions | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004
13 | Contraceptive use | 1988
15 | Infant mortality rates | 1996–1999, 2001–2004
16 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001–2004
17 | Infant mortality rates | 1981–1989, 1991–1994, 1996–1999, 2001–2002
20 | International mortality rates and rankings | 2001–2005
21 | International life expectancy | 1995, 1999, 2001–2007
22 | Life expectancy | 1975, 1981–1989, 1991–1994, 1996–1998
24 | Age-adjusted death rates for selected causes | 1981–1989, 1991–1999, 2001–2004, 2006
25 | Years of potential life lost | 1991–1999, 2001–2004, 2006; crude 1999–2007
28 | Urbanization level | 2002–2004, 2003–2005, 2004–2006, 2005–2007
29 | Death rates for all causes | 1981–1989, 1991–1999, 2001–2006
30 | Diseases of heart | 1981–1989, 1991–1999, 2001–2006
31 | Cerebrovascular diseases | 1981–1989, 1991–1999, 2001–2006
32 | Malignant neoplasms | 1981–1989, 1991–1999, 2001–2006
33 | Malignant neoplasms of trachea, bronchus, and lung | 1981–1989, 1991–1999, 2001–2006
34 | Malignant neoplasm of breast | 1981–1989, 1991–1999, 2001–2006
35 | Human immunodeficiency virus (HIV) disease | 1988–1989, 1991–1994, 2001–2004, 2006
36 | Drug poisoning | 2006
37 | Motor vehicle-related injuries | 1981–1989, 1991–1999, 2001–2006
38 | Homicide | 1981–1989, 1991–1999, 2001–2006
39 | Suicide | 1981–1989, 1991–1999, 2001–2006
40 | Firearm-related injuries | 1981–1989, 1991–1994, 1996–1999, 2001–2004, 2006
41 | Occupational diseases | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006
43 | Nonfatal occupational injuries and illnesses | 2004–2006
44 | Notifiable diseases | 1985, 1988–1989, 1991–1999, 2001–2006
46 | Health conditions among children | 2006–2008, 2007–2009
47 | Cancer incidence rates | 1991–1994, 1996–1999, 2001, 2004
48 | Five-year relative cancer survival rates | 1978–1980, 1984–1986, 1990–1992, 1993–1995
49 | Respondent-reported prevalence of heart disease, cancer, and stroke | 2001–2002, 2003–2004, 2005–2006, 2008–2009
50 | Diabetes | 2001–2004
51 | End-stage renal disease | 1981–1989, 1991–1999, 2001–2006
52 | Severe headache or migraine, low back pain, and neck pain | 1998–2008
53 | Joint pain | 2003–2008
54 | Basic actions difficulty and complex activity limitation | 1998–1999, 2001–2008
55 | Vision and hearing limitations | 1998–1999, 2001–2008
56 | Respondent-assessed health status | 1998–1999, 2001–2004, 2006–2007
59 | Serious psychological distress | 2000–2001, 2002–2003, 2003–2004, 2006–2007, 2008–2009
60 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001–2004, 2006,2007
61 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001–2004, 2006, 2007
62 | Cigarette smoking | 1993–1995, 2006–2008, 2007–2009
64 | Use of selected substances | 2003–2006
65 | Use of selected substances | 1981–1984, 1986–1989, 1992–1994, 1996–1999, 2001–2006
67 | Health risk behaviors among students | 1993, 1995, 1997, 1999, 2001, 2003, 2005
68 | Heavier drinking and drinking five or more drinks in a day | 1998–1999, 2001–2008
70 | Hypertension (high blood pressure) | 2001–2004, 2005–2008
71 | Cholesterol | 2001–2004, 2005–2008
72 | Mean energy and macronutrient intake | 2003–2006
73 | Leisure-time aerobic/muscle-strengthing physical activity | 1999, 2001–2008
74 | Overweight, obesity, and healthy weight | 1999–2002, 2001–2004, 2005–2008
75 | Overweight among children and adolescents | 2001–2004, 2005–2008
76 | Untreated dental caries | 2001–2004
77 | No usual source of health care, children | 1995–1996, 1997–1998, 2001–2002, 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2007–2008, 2008–2009
78 | No usual source of health care, working-age adults | 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2008–2009
79 | Reduced access to medical care | 1998–2008
81 | Reduced access to medical care | 1998–1999, 1999–2000, 2000–2001, 2002–2003, 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2007–2008, 2008–2009
82 | No health care visits | 1999–2000, 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2007–2008, 2008–2009
83 | Health care visits | 1998–2008
84 | International influenza vaccination | 2001–2002
85 | Vaccinations | 1996–1999, 2001–2003
86 | Vaccinations | 2003
88 | Influenza vaccination | 1991, 1993–1994, 1997–1999, 2001–2004, 2006
89 | Pneumococcal vaccination | 1991, 1993–1994, 1997–1999, 2001–2004, 2006
90 | Mammography | 1991, 1998, 1999
91 | Pap smears | 1998, 2003
93 | Emergency department visits for children | 1998–2008
94 | Emergency department visits for adults | 1998–1999, 2001–2008
95 | Injury-related visits to hospital emergency departments | 2007–2008
96 | Ambulatory care visits | 1997–1999, 2001–2007
97 | Ambulatory care visits | 1997–1999, 2001–2008
98 | Dental visits | 1998–2008
99 | Prescription drug use | 1999–2002, 2003–2006
100 | Prescription drug use by drug class | 2001–2004, 2003–2006
101 | Dietary supplement use | 2001–2004, 2003–2006
102 | Discharges | 1998–1999, 2001–2008
103 | Discharges | 1991–1994, 1996–1999, 2001–2004, 2006, 2008, 2009
104 | Days of care | 1991–1999, 2001–2009
105 | Diagnoses | 1991–1999, 2001–2009
106 | Average length of stay | 1991–1999, 2001–2009
107 | Procedures | 1991–1999, 2001–2009
113 | Employees and wages | 2002–2003, 2005–2007, 2009
117 | Mental health organizations | 1992, 1998
120 | Nursing homes | 1996–1999, 2001–2008
121 | Certified intermediate care facilities | 2000, 2007, 2009
122 | Medicare-certified providers and suppliers | 1997–1999, 2001, 2002, 2004, 2006, 2008
123 | Magnetic Resonance Imaging (MRI) units and Computed Tomography (CT) scanners | 2001–2006
124 | Total health expenditures as a percent of gross domestic product | 1961–1969, 1971–1979, 1981–1989, 1991–1994, 1996–1999, 2001–2004
126 | Consumer Price Index | 2007–2008
129 | Personal health care expenditures | 1999, 2001–2006
130 | Expenditures for mental health services | 1987–1989, 1991–1994, 1996–1999, 2001–2003
131 | Expenditures for substance abuse treatment | 1987–1989, 1991–1994, 1996–1999, 2001–2003
132 | Cost of hospital discharges | 2006–2008
133 | Expenditures for health care | 1996, 1998–1999, 2001–2007
134 | Sources of payment for health care | 1996, 1998–1999, 2001–2007
135 | Out-of-pocket health care expenses | 1998–1999, 2001–2004, 2006
136 | Expenditures for health services and supplies | 2003, 2004, 2006
137 | Employers’ costs and health insurance | 1992–1993, 1995, 1997–1999, 2001–2006
138 | Private health insurance | 1994, 1998, 1999, 2001–2004, 2006, 2007
139 | Private health insurance | 1994, 1998, 1999, 2001–2004, 2006, 2007
140 | Medicaid coverage | 1994, 1998, 1999, 2001–2003, 2005–2007
141 | No health insurance coverage | 1994, 1998–1999, 2001–2003, 2005–2007
142 | Health care coverage | 1993–1994, 1996–1999, 2001–2006
143 | Medicare | 2006–2007
144 | Medicare | 1996–1998, 2001, 2003–2004, 2006
145 | Medicare | All: 1999–2005; 1993–2005
146 | Medicaid | 2001, 2002
147 | Medicaid | 2001, 2002
148 | Department of Veterans Affairs | 1985, 1988–1989, 1991–1994, 1996–1999, 2001–2004, 2006, 2007
149 | Medicare | 1995–2008
150 | Medicaid | 2001–2008
151 | Persons without health insurance coverage | 2004–2006, 2005–2007, 2006–2008