# Data Sources

Health, United States consolidates the most current data on the health of the population of the United States, the availability and use of health resources, and health care expenditures. Information was obtained from the data files and published reports of many federal government, private, and global agencies and organizations. In each case, the sponsoring agency or organization collected data using its own methods and procedures. Therefore, data in this report may vary considerably with respect to source, method of collection, definitions, and reference period.

Although a detailed description and comprehensive evaluation of each data source are beyond the scope of this appendix, readers should be aware of the general strengths and weaknesses of the different data collection systems. For example, population-based surveys obtain socioeconomic data, data on family characteristics, and information on the impact of an illness, such as days lost from work or limitation of activity. These data are limited by the amount of information a respondent remembers or is willing to report. For example, a respondent may not know detailed medical information, such as a precise diagnosis or the type of procedure performed, and therefore cannot report that information. In contrast, records-based surveys, which collect data from physician and hospital records, usually contain good diagnostic information but little or no information about the socioeconomic characteristics of individuals or the impact of illnesses on individuals.

Different data collection systems may cover different populations, and understanding these differences is critical to interpreting the resulting data. Data on vital statistics and national expenditures cover the entire population. However, most data on morbidity and the utilization of health resources cover only the civilian noninstitutionalized population and thus may not include data for military personnel, who are usually young; for institutionalized people, including the prison population, who may be of any age; or for nursing home residents, who are usually older.

All data collection systems are subject to error, and records may be incomplete or contain inaccurate information. Respondents may not remember essential information, a question may not mean the same thing to different respondents, and some institutions or individuals may not respond at all. It is not always possible to measure the magnitude of these errors or their effect on the data. Where possible, table notes describe the universe and method of data collection to assist users in evaluating data quality.

Some information is collected in more than one survey, and estimates of the same statistic may vary among surveys because of different survey methodologies, sampling frames, questionnaires, definitions, and tabulation categories. For example, cigarette use is measured by the National Health Interview Survey, the National Survey on Drug Use & Health, the Monitoring the Future Study, and the Youth Risk Behavior Survey. These surveys use slightly different questions, cover persons of differing ages, and interview in diverse settings (e.g., at school compared with at home), so estimates will differ.

Overall estimates generally have relatively small sampling errors, but estimates for certain population subgroups may be based on a small sample size and have relatively large sampling errors. Numbers of births and deaths from the National Vital Statistics System represent complete counts (except for births in those states where data are based on a 50% sample for certain years). Therefore, these data are not subject to sampling error. However, when the figures are used for analytical purposes, such as the comparison of rates over a period, the number of events that actually occurred may be considered as one of a large series of possible results that could have arisen under the same circumstances. When the number of events is small and the probability of such an event is rare, estimates may be unstable, and considerable caution must be used in interpreting the statistics. Estimates that are unreliable because of large sampling errors or small numbers of events are noted with asterisks in tables, and the criteria used to designate unreliable estimates are indicated in an accompanying footnote.

In this appendix, government data sources are listed alphabetically by data set name, and private and global sources are listed separately. To the extent possible, government data systems are described using a standard format. The Overview is a brief, general statement about the purpose or objectives of the data system. The Selected Content section lists major data elements that are collected or estimated using interpolation or modeling. The Data Years section gives the years that the survey or data system has existed or been fielded. The Coverage section describes the population that the data system represents: for example, residents of the United States, the noninstitutionalized population, persons in specific population groups, or other entities that make up the survey. The Methodology section presents a short description of the methods used to collect data. The Sample Size and Response Rate section provides these statistics for surveys. The Issues Affecting Interpretation section describes major changes in the data collection methodology or other factors that must be considered when analyzing trends: for example, a major survey redesign that may introduce a discontinuity in the trend. For additional information about the methodology, data files, and history of a data source, consult the References and For More Information sections that follow each summary.

## Government Sources

### Abortion Surveillance System

#### CDC/National Center for Chronic Disease Prevention and Health Promotion (NCCDPHP)

##### Overview

The Abortion Surveillance System documents the number and characteristics of women obtaining legal induced abortions, monitors teenage and unintended pregnancy, and assists in efforts to identify and reduce preventable causes of morbidity and mortality associated with abortions.

##### Selected Content

Content includes age, race, ethnicity, marital status, previous live births, period of gestation, and previous induced abortions among women obtaining legal induced abortions.

##### Data Years

Between 1973 and 1997, the number of abortions is based on reporting from 52 reporting areas: 50 states, the District of Columbia, and New York City. In 1998 and 1999, CDC compiled abortion data from 48 reporting areas. Alaska, California, New Hampshire, and Oklahoma did not report, and data for these areas were not estimated. In 2000–2004, CDC compiled data from 49 reporting areas. Alaska, California, and New Hampshire did not report abortion data to CDC in 2000–2002. In 2003 and 2004, California, New Hampshire, and West Virginia did not report. In 2005, California, Louisiana, and New Hampshire did not report. In 2006, California and New Hampshire did not report. In 2007, California, Maryland, and New Hampshire did not report.

##### Coverage

The system includes women of all ages, including adolescents, who obtain legal induced abortions.

##### Methodology

Each year, CDC requests tabulated data from the central health agencies of 52 reporting areas (the 50 states, the District of Columbia, and New York City) to document the number and characteristics of women obtaining abortions in the United States. For the purpose of surveillance, a legal induced abortion is defined as an intervention performed by a licensed clinician (e.g., a physician, nurse-midwife, nurse practitioner, or physician assistant) that is intended to terminate a suspected or known ongoing intrauterine pregnancy and produce a nonviable fetus at any gestational age.

In most states, collection of abortion data is facilitated by the legal requirement for hospitals, facilities, and physicians to report abortions to a central health agency. These central health agencies voluntarily provide CDC the aggregate numbers for the abortion data they have collected. Although reporting to CDC is voluntary, most reporting areas provide aggregate abortion numbers; during 1999–2008, a total of 45 reporting areas provided CDC a continuous annual record of abortion numbers.

##### Issues Affecting Interpretation

The abortion data in this report are subject to at least four limitations. First, because reporting requirements are established by the individual reporting areas, the collection of data varies, and thus CDC is unable to obtain the total number of abortions performed in the United States. During 1999–2008, the total annual number of abortions recorded by CDC was 65%–69% of the number recorded by The Guttmacher Institute (a not-for-profit organization for reproductive health research, policy analysis, and public education that has an abortion provider surveillance program). Although most reporting areas collect and send abortion data to CDC, this information is given to CDC voluntarily. During 1999–2008, 7 of the 52 reporting areas did not provide CDC with data on a consistent annual basis. In addition, whereas most of the reporting areas that send abortion data to CDC have laws requiring medical providers to submit a report for every abortion they perform to a central health agency, in New Jersey and the District of Columbia medical providers submit this information voluntarily. As a result, the abortion numbers these areas report to CDC tend to be incomplete. Even in states that legally require medical providers to submit a report for all the abortions they perform, enforcement of this requirement varies, thus several other reporting areas provide CDC with comparatively incomplete numbers. Second, because reporting requirements are established by the individual reporting areas, many states have developed reporting forms that do not resemble the example CDC created for technical guidance.

Consequently, many reporting areas do not collect all the information CDC compiles on the characteristics of women obtaining abortions (e.g., age, race, and ethnicity). Similarly, some reporting areas do not specifically include medical abortion as one of the potential methods for terminating a pregnancy. Third, abortion data are compiled and reported to CDC by the central health agency of the reporting area in which the abortion was performed rather than the reporting area in which the woman lived. This inflates abortion statistics for reporting areas in which a high percentage of abortions are obtained by out-of-state residents and undercounts abortions for states with limited abortion services, more stringent legal requirements for obtaining an abortion, or geographic proximity to services in another state. To adjust for these biases, CDC attempts to categorize abortions by residence in addition to occurrence. However, CDC was unable to identify the reporting area, territory, or country of residence for 11.5% of abortions reported in 2008, and this missing information may affect state estimates. Finally, adjustments for socioeconomic status cannot be made without data on education or income, and joint analysis of many variables of interest (e.g., age, race, and ethnicity) is precluded because reporting areas provide CDC with aggregate numbers rather than individual-level records.

##### Reference

Pazol K, Zane SB, Parker WY, Hall LR, Berg C, Cook DA. Abortion surveillance—United States, 2008. MMWR Surveill Summ. 2011;60(SS–15):1-41. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/ss6015a1.htm.

##### For More Information

See the NCCDPHP surveillance and research website at: http://www.cdc.gov/reproductivehealth/Data_Stats/index.htm.

### Census of Fatal Occupational Injuries (CFOI)

#### Bureau of Labor Statistics (BLS)

##### Overview

CFOI compiles comprehensive and timely information on fatal work injuries occurring in the 50 states and the District of Columbia (D.C.), to monitor workplace safety and to inform private and public health efforts to improve workplace safety.

##### Selected Content

Information is collected about each workplace fatal work injury, including occupation and other worker characteristics, equipment involved, and circumstances of the event.

##### Data Years

Data have been collected annually since 1992.

##### Coverage

The data cover all 50 states and D.C.

##### Methodology

CFOI is administered by BLS, in conjunction with participating state agencies, to compile counts that are as complete as possible to identify, verify, and profile fatal work injuries. Key information about each workplace fatal injury (occupation and other worker characteristics, equipment or machinery involved, and circumstances of the event) is obtained by cross-referencing source documents. For a fatal occupational injury to be included in the census, the decedent must have been employed (that is, self-employed, working for pay, or volunteering) at the time of the event, engaged in a legal work activity, or present at the site of the incident as a requirement of his or her job. These criteria are generally broader than those used by federal and state agencies administering specific laws and regulations. Fatal work injuries that occur during a person’s commute to or from work are excluded from the census counts. Fatal work injuries to volunteer workers who are exposed to the same work hazards and perform the same duties or functions as paid employees and that meet the CFOI work relationship criteria are included.

Data for CFOI are compiled from various federal, state, and local administrative sources, including death certificates, workers’ compensation reports and claims, reports to various regulatory agencies, medical examiner reports, police reports, and news reports. Diverse sources are used because studies have shown that no single source captures all job-related fatal injuries. Source documents are matched so that each fatal work injury is counted only once. To ensure that a fatal work injury occurred while the decedent was at work, information is verified from two or more independent source documents or from a source document and a follow-up questionnaire.

Denominator data for the calculation of fatal work injury rates are provided by the Current Population Survey (CPS). CPS and CFOI differ in scope. Where these differences occur, CFOI-adjusted fatal work injury counts are used in calculating the rates, to maintain consistency between the rate numerator (number of fatal work injuries) and the denominator (annual average employment and/or total hours worked). Workers under 16 years of age are excluded from fatal injury rate data. Starting with 2008 data, volunteers and military personnel also are excluded. Volunteers and military personnel are not included in the CPS data, and CFOI has been unable to obtain reliable hours-worked data for these groups. Prior to 2008, the employment numbers used to calculate the military rate were supplied by the U.S. Census Bureau (1995–1998) and the Department of Defense (1999–2008).

##### Issues Affecting Interpretation

The number of fatal occupational injuries and fatal injury rates is revised periodically. States have up to 8 months to update their initial published counts and may identify additional fatal work injuries after data collection has closed for a reference year. Fatal work injuries initially excluded from the published count because of insufficient information to determine work relationship may subsequently be verified as work-related and included in the revised counts and rates. Increases in the published counts over the last 5 years based on additional information have averaged approximately 138 fatal occupational injuries per year, or less than 3% of the annual total.

Prior to 2003, CFOI used the Standard Industrial Classification (SIC) system and the U.S. Census Bureau’s occupational classification system to classify industries. Beginning with 2003 data, CFOI began using the 2002 North American Industry Classification System (NAICS). Although some titles in SIC and NAICS are similar, there is limited comparability between the two systems because the industry groupings are defined differently. Starting with 2009 data, CFOI began using the 2007 NAICS to classify industries. In Health, United States, industry data are presented at the two-digit level. Most of the differences between the 2002 and 2007 NAICS are at a more detailed level. Therefore, the adoption of the 2007 NAICS for CFOI is unlikely to affect the trend presented in Health, United States. (See Appendix II, Industry of employment.)

Starting with 2008 data, fatal injury rates presented in Health, United States are based on hours rather than employment, and consequently are not directly comparable with earlier injury rate data. Hours-based rates standardize the amount of exposure and are considered more accurate than employment-based rates. Hours-based rates use the average number of employees at work and the average hours each employee works annually. Employment- and hours-based rates will be similar for groups of workers who usually work full time. Differences in these rates are more likely for groups of workers who have a high percentage of part-time workers, such as younger workers. Hours-worked data are provided by CPS. For more information, see: http://www.bls.gov/iif/oshnotice10.htm.

##### Reference

Bureau of Labor Statistics. National Census of Fatal Occupational Injuries in 2009. [press release]. USDL–10–1142. Washington, DC. U.S. Department of Labor. 2010. August. 19. Available from: http://www.bls.gov/news.release/archives/cfoi_08192010.pdf.

##### For More Information

See the CFOI website at: http://www.bls.gov/iif/oshcfoi1.htm and the CFOI section of the BLS Handbook of Method at: http://www.bls.gov/opub/hom/homch9.htm#census_fatal.

### Consumer Price Index (CPI)

#### Bureau of Labor Statistics (BLS)

##### Overview

The CPI is a measure of the average change in prices over time of goods and services purchased by households. It is designed to produce a monthly measure of the average change in the prices of goods and services purchased by urban consumers.

##### Selected Content

Price indexes are available for the United States, the four census regions, size of city, cross-classifications of regions and size-classes, and 27 local areas. Indexes are available for major groups of consumer expenditures (food and beverages, housing, apparel, transportation, medical care, recreation, education and communications, and other goods and services), for items within each group, and for special categories such as services. Monthly indexes are available for the United States, the four census regions, and some local areas. For other local areas, data are bimonthly or semiannual.

BLS publishes CPIs for two population groups: urban wage earners and clerical workers (CPI–W), and all urban consumers (CPI–U). CPI–W covers households of wage earners and clerical workers. CPI–U and the chained CPI for all urban consumers (C–CPI–U) include, in addition to wage earner and clerical worker households, groups such as professional, managerial, and technical workers, the self-employed, short-term workers, the unemployed, and retirees and others not in the labor force.

##### Data Years

Data are available back to 1913. Prior to 1978, the data are based on the CPI–W population.

##### Coverage

CPI–W covers 32% of the U.S. population. CPI–U, introduced in 1978, covers residents of metropolitan areas and residents of urban parts of nonmetropolitan areas (about 87% of the U.S. population in 2000).

##### Methodology

In calculating the index, price changes for the various items in each location are averaged together with weights that represent their importance in the spending of all urban consumers. Local data are aggregated to obtain a U.S. city average.

The index measures price changes from a designated reference date, 1982–1984, which equals 100. An increase of 22%, for example, is shown as 122. Change can also be expressed in dollars, for example: The price of a base period market basket of goods and services bought by all urban consumers has risen from $100 in 1982–1984 to $218 in 2010.

The CPI currently reflects spending patterns based on the Survey of Consumer Expenditures during 2007–2008, the 1990 Census of Population, and the ongoing Point-of-Purchase Survey. Using an improved sample design, prices for the goods and services required to calculate the index are collected in urban areas throughout the country and from retail and service establishments. Data on rents are collected from tenants of rented housing and residents of owner-occupied housing units. Food, fuels, and a few other goods and services are priced monthly in all urban locations. Price information is obtained through visits or calls by trained BLS field representatives using computer-assisted telephone interviews.

##### Issues Affecting Interpretation

A 1987 revision changed the treatment of health insurance in the cost-weight definitions for medical care items. This change has no effect on the overall index result but provides a clearer picture of the role of health insurance in the CPI. As part of the revision, three new indexes were created by separating previously combined items; for example, eye care is separated from other professional services, and inpatient and outpatient treatment are separated from other hospital and medical care services.

Effective January 1997, the hospital index was restructured by combining the three categories room, inpatient services, and outpatient services into one category: hospital services. In addition, new procedures for hospital data collection identify a payer, diagnosis, and the payer’s reimbursement arrangement from selected hospital bills.

##### References

Bureau of Labor Statistics. BLS handbook of methods. BLS bulletin no 2490. Washington, DC. U.S. Department of Labor. 1997. Available from: http://www.bls.gov/opub/hom/.
Bureau of Labor Statistics. Revising the Consumer Price Index. Mon Labor Rev. 1996;119(12).
Ford IK, Ginsburg DH. Medical care in the Consumer Price Index. Cutler DM, Berndt ER, editors. Medical care output and productivity. Bureau of Economic Research studies in income and wealth. Chicago, IL. University of Chicago Press. 2001;62:203-19.

##### For More Information

See the BLS/CPI website at: http://www.bls.gov/cpi.

### Current Population Survey (CPS)

#### Bureau of Labor Statistics (BLS) and U.S. Census Bureau

##### Overview

CPS provides current estimates and trends in employment, unemployment, and other characteristics of the general labor force, the population as a whole, and various population subgroups.

##### Selected Content

The CPS interview is divided into three basic parts: (a) household and demographic information, (b) labor force information, and (c) supplement information for months that include supplements. Comprehensive work experience information is gathered on the employment status, occupation, and industry of persons interviewed.

Estimates of poverty and health insurance coverage presented in Health, United States from CPS are derived from the Annual Social and Economic Supplement (ASEC), formerly called the Annual Demographic Supplement (ADS) and commonly called the March Supplement. ASEC collects data on family characteristics, household composition, marital status, migration, income from all sources, information on weeks worked, time spent looking for work or on layoff from a job, occupation and industry classification of the job held longest during the year, health insurance coverage, and receipt of noncash benefits such as food stamps, school lunch program, employer-provided group health insurance plan, employer-provided pension plan, personal health insurance, Medicaid, Medicare, CHAMPUS or military health care, and energy assistance.

##### Data Years

The basic CPS has been conducted since 1945, although some data were collected prior to that time. The U.S. Census Bureau has collected data in the ASEC or ADS since 1947.

##### Coverage

The Census-2000-based basic CPS sample was introduced in April 2004, and implementation was completed by July 2005 with coverage in every state and the District of Columbia. For CPS labor force data, the adult universe (i.e., the population of marriageable age) is composed of persons 15 years of age and over in the civilian noninstitutionalized population. The sample for the March CPS supplement is expanded to include members of the Armed Forces who are living in a household that includes at least one civilian adult, as well as additional Hispanic households that are not included in the monthly labor force estimates.

##### Methodology

The basic CPS sample is selected from multiple frames using multiple stages of selection. Each unit is selected with a known probability to represent similar units in the universe. The sample design is state-based, with the sample in each state being independent of the others.

One person generally responds for all eligible members of a household. For those who are employed, employment information is collected for the job held in the reference week. The reference week is defined as the 7-day period, Sunday through Saturday, that includes the 12th of the month. In CPS, a person with two or more jobs is classified according to the job at which he or she worked the greatest number of hours. In general, BLS publishes labor force data only for persons 16 years of age and over because those under 16 years are substantially limited in their labor market activities by compulsory schooling and child labor laws. No upper age limit is used, and full-time students are treated the same as nonstudents.

The additional Hispanic sample is from the previous November’s basic CPS sample. If a person is identified as being of Hispanic origin from the November interview and is still residing at the same address in March, that housing unit is eligible for the March survey. This amounts to a near doubling of the Hispanic sample because there is no overlap of housing units between the basic CPS samples in November and March.

For all CPS data files, a single weight is prepared and used to compute the monthly labor force status estimates. An additional weight is prepared for the earnings universe that roughly corresponds to wage and salary workers in the two outgoing rotations. The final weight is the product of the basic weight, the adjustments for special weighting, the noninterview adjustment, the first-stage ratio adjustment factor, and the second-stage ratio adjustment factor. This final weight should be used when producing estimates from the basic CPS data. Differences in the questionnaire, sample, and data uses for the March CPS supplement result in the need for additional adjustment procedures to produce what is called the March Supplement weight.

##### Sample Size and Response Rate

Beginning with 2001, the Children’s Health Insurance Program (CHIP) sample expansion was introduced. This included an increase in the basic CPS sample to 60,000 households per month. Prior to 2001, estimates were based on 50,000 households per month. The expansion also included an additional 12,000 households that were allocated differentially across states, based on prior information of the number of uninsured children in each state, to produce statistically reliable current state data on the number of low-income children who do not have health insurance coverage. In an average month, the nonresponse rate for the basic CPS is about 7%–8%.

##### Issues Affecting Interpretation

Over the years, the number of income questions has expanded, questions on work experience and other characteristics have been added, and the month of interview was moved to March. In 2002, an ASEC sample increase was implemented, requiring more time for data collection. Thus, additional ASEC interviews are now taking place in February and April. However, even with this sample increase, most of the data collection still occurs in March.

In 1994, major changes were introduced that included a complete redesign of the questionnaire to include new health insurance questions and the introduction of computer-assisted interviewing for the entire survey. In addition, some of the labor force concepts and definitions were revised. Prior to the redesign, CPS data were primarily collected using a paper-and-pencil form. Beginning in 1994, population controls were based on the 1990 census and adjusted for the estimated population undercount. Starting with Health, United States, 2003, poverty estimates for data years 2000 and beyond were recalculated based on the expanded CHIP sample, and Census 2000-based population controls were implemented. Starting with 2002 health insurance data, 1997 race standards were implemented that allowed respondents to report more than one race.

##### Reference

U.S. Census Bureau. Current Population Survey: Design and methodology. Technical paper 66. Washington, DC. U.S. Census Bureau. 2006. Available from: http://www.census.gov/prod/2006pubs/tp-66.pdf.

##### For More Information

See the CPS website at: http://www.census.gov/cps.

### Department of Veterans Affairs National Enrollment and Patient Databases

#### Department of Veterans Affairs (VA)

##### Overview

The VA compiles and analyzes multiple data sets on the health and health care of its clients and other veterans to monitor access and quality of care and to conduct program and policy evaluations.

##### Selected Content

The VA maintains the National Patient Care Database (NPCD), the Patient Treatment file (PTF), and the National Enrollment Database (NED).

The NPCD and PTF are nationwide systems that contain a statistical record for each episode of care provided under VA auspices, in VA and non-VA hospitals, nursing homes, VA residential rehabilitation treatment programs (formerly called domiciliaries), and VA outpatient clinics. Three major extracts are the PTF, the Patient Census file (PCF), and the NPCD.

The PTF collects data at the time of the patient’s discharge on each episode of inpatient care provided to patients at VA hospitals, VA nursing homes, VA residential rehabilitation treatment programs, community nursing homes, and other non-VA facilities. The PTF record contains unique patient identifiers, dates of inpatient treatment, date of birth, state and county of residence, type of disposition, place of disposition after discharge, and International Classification of Diseases, 9th Revision, Clinical Modification (ICD–9–CM) diagnostic and procedure or operative codes for each episode of care.

The PCF collects data on each patient remaining in a VA medical facility at midnight at the end of each quarter of the fiscal year. The census record includes information similar to that reported in the PTF record.

The NPCD collects data on each instance of medical treatment provided to a veteran in an outpatient setting. The NPCD record includes the age, unique patient identifiers, state and county of residence, VA eligibility code, clinic(s) visited, purpose of visit, and date of visit for each episode of care.

The VA also maintains the NED as the official repository of enrollment information for each veteran enrolled in the VA health care system.

##### Coverage

U.S. veterans who receive services within the VA medical system are included. Data are available for some nonveterans who receive care at VA facilities.

##### Methodology

The NPCD and PTF are the source data for the Veterans Health Administration (VHA) Medical SAS Datasets. The NPCD and PTF are also the VHA’s centralized relational databases (a data warehouse) that receive encounter data from VHA clinical information systems. The databases are updated daily. Data are collected locally at each VA medical center and transmitted electronically to the VA’s Austin Automation Center for use in providing nationwide statistics, reports, and comparisons.

##### Issues Affecting Interpretation

The databases include users of the VA health care system. VA eligibility is a hierarchy based on service-connected disabilities, income, age, and availability of services. Therefore, different VA programs may serve populations with different sociodemographic characteristics than those served by other health care systems.

##### For More Information

See the VA Information Resource Center website at: http://www.virec.research.va.gov/Support/Training-NewUsersToolkit/IntroToVAData.htm.

### Employee Benefits Survey—See National Compensation Survey (NCS)

### Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample

#### Agency for Healthcare Research and Quality

##### Overview

HCUP is a family of health care databases and related software tools developed through a federal-state-industry partnership to build a multistate health data system for health care research and decision making. The Nationwide Inpatient Sample (HCUP–NIS), a component of HCUP, is the largest all-payer inpatient care database that is publicly available in the United States, containing data from 5 to 8 million hospital stays from about 1,000 hospitals, sampled to approximate a 20% stratified sample of U.S. community hospitals.

##### Selected Content

HCUP–NIS contains a core set of clinical and nonclinical information found in a typical discharge abstract, including all-listed diagnoses and procedures, discharge status, patient demographics, and charges for all patients regardless of payer (e.g., persons covered by Medicare, Medicaid, and private insurance, as well as those without insurance coverage).

##### Data Years

HCUP–NIS data releases are available for data years beginning in 1988. The number of states in HCUP–NIS varies by year.

##### Coverage

HCUP–NIS for 2009 includes 1,050 hospitals from 44 states, which contain about 95% of all U.S. community hospital discharges. The number of states participating in HCUP–NIS has increased each year, from 28 states in 2000 to 37 states in 2005, 38 states in 2006, 40 states in 2007, and 42 states in 2008. The states included in the 2000 data set were Arizona, California, Colorado, Connecticut, Florida, Georgia, Hawaii, Illinois, Iowa, Kansas, Kentucky, Maine, Maryland, Massachusetts, Missouri, New Jersey, New York, North Carolina, Oregon, Pennsylvania, South Carolina, Tennessee, Texas, Utah, Virginia, Washington, West Virginia, and Wisconsin. Starting in 2005, Arkansas, Indiana, Michigan, Minnesota, Nebraska, Nevada, New Hampshire, Ohio, Oklahoma, Rhode Island, South Dakota, and Vermont joined the sample, and Maine, Pennsylvania, and Virginia left HCUP–NIS. Starting in 2006, Virginia rejoined the sample, and starting in 2007 Maine and Wyoming were added. Starting in 2008, Louisiana and Pennsylvania were added. Starting in 2009, Montana and New Mexico were added, resulting in 44 states in HCUP–NIS.

##### Methodology

HCUP–NIS is designed to approximate a 20% sample of U.S. community hospitals (excluding rehabilitation hospitals), defined by the American Hospital Association to be all nonfederal, short-term, general, and other specialty hospitals, excluding hospital units of institutions. This universe of U.S. community hospitals is divided into strata using five hospital characteristics: ownership and control, bed size, teaching status, urban or rural location, and U.S. region. HCUP–NIS is a stratified probability sample of hospitals in the frame, with sampling probabilities proportional to the number of U.S. community hospitals in each stratum. The frame is limited by the availability of inpatient data from the data sources currently participating in HCUP.

The information abstracted from hospital discharge records is translated into a uniform format to facilitate both multistate and national-state comparisons and analyses.

Hospital costs are derived from total hospital charges using hospital-specific cost-to-charge ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. Costs will tend to reflect the actual costs to produce hospital services, whereas charges represent what the hospital billed for the care. Costs are adjusted for economy-wide inflation by removing increases that reflect the effect of changing average prices for the same goods and services. The U.S. Bureau of Economic Analysis Gross Domestic Product Price Index is used to remove economy-wide inflation. Additional inflation that is specific to the hospital sector is not removed in this calculation.

##### Sample Size and Response Rate

The 2009 HCUP–NIS contains data from 7.8 million hospital stays from 1,050 hospitals; this approximates a 20% stratified sample of U.S. community hospitals. The Inpatient Core file (the HCUP–NIS inpatient discharge-level file) contains data for 100% of the discharges from a sample of hospitals in participating states.

##### Issues Affecting Interpretation

Weights are produced to create national estimates, but because the number of participating states has increased over time, estimates from earlier years may be biased if omitted states have substantially different hospitalization patterns than states that provided data.

##### Reference

Agency for Healthcare Research and Quality (AHRQ). Introduction to the HCUP Nationwide Inpatient Sample (NIS), 2009. Healthcare Cost and Utilization Project—HCUP: A federal-state-industry partnership in health data. Rockville, MD. AHRQ. 2011. Available from: https://www.hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf.

##### For More Information

See the HCUP website at: http://www.hcup-us.ahrq.gov/.

### HIV/AIDS Reporting System (HARS)

#### CDC/National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention (NCHHSTP)

##### Overview

Acquired immunodeficiency syndrome (AIDS) surveillance data are used to detect and monitor cases of human immunodeficiency virus (HIV) disease and AIDS in the United States, identify epidemiologic trends, identify unusual cases requiring follow-up, and inform public health efforts to prevent and control the disease.

##### Selected Content

Data collected on cases diagnosed with AIDS include age, sex, race, ethnicity, mode of exposure, and geographic region.

##### Data Years

Reports on AIDS cases are available from the beginning of the epidemic that started in 1981.

##### Coverage

All 50 states, the District of Columbia (D.C.), U.S. dependencies and possessions, and independent nations in free association with the United States report AIDS cases to CDC using a uniform surveillance case definition and case report form. As of April 2008, all states had implemented confidential, name-based HIV infection reporting and agreed to participate in CDC’s integrated HIV/AIDS surveillance system.

##### Methodology

AIDS surveillance is conducted by health departments in each state or territory and D.C. Although surveillance activities range from passive to active, most areas employ multifaceted active surveillance programs, which include four major reporting sources of AIDS information: hospitals and hospital-based physicians, physicians in nonhospital practice, public and private clinics, and medical record systems (death certificates, tumor registries, hospital discharge abstracts, and communicable disease reports). Using a standard confidential case report form, the health departments collect information that is then transmitted electronically, without personal identifiers, to CDC.

Adjustments of the estimated data on HIV infection (not AIDS) and AIDS to account for reporting delays are calculated by a maximum-likelihood statistical procedure that takes into account the differences in reporting delays among exposure, geographic, race and ethnicity, age, sex, and vital status categories and is based on the assumption that reporting delays in these categories have not changed over time. AIDS surveillance data are provisional and are updated annually.

##### Issues Affecting Interpretation

Although the completeness of reporting of AIDS cases to state and local health departments differs by geographic region and patient population, studies conducted by state and local health departments indicate that the reporting of AIDS cases in most areas of the United States is more than 85% complete. To assess trends in AIDS cases, deaths, and prevalence, it is preferable to use case data adjusted for reporting delays and presented by year of diagnosis, rather than straight counts of cases presented by year of report.

The definition of AIDS was modified in 1985 and 1987. The case definition for adults and adolescents was modified again in 1993. The revisions incorporated a broader range of AIDS-indicator diseases and conditions and used HIV diagnostic tests to improve the sensitivity and specificity of the definition. Laboratory and diagnostic criteria for the 1987 pediatric case definition were updated in 1994. Effective January 2000, the surveillance case definition for HIV infection was revised to reflect advances in laboratory HIV virologic tests. The definition incorporates the reporting criteria for HIV infection and AIDS into a single case definition for adults and children.

In 2008, changes were made to the case definition for HIV infection. The new case definition combined the two previous case definitions for HIV and AIDS and established a new disease staging classification. This change in the new case definition prompted changes to the title of the report and new terminology for diagnoses of HIV infection and AIDS throughout the report. The term “HIV/AIDS”—previously used to refer to a new diagnosis of HIV infection regardless of the person’s disease stage at the time of diagnosis—was replaced with the term “diagnosis of HIV infection,” to reflect implementation of the revised case definition for HIV infection that incorporated the previous case definition for AIDS and established a new disease staging classification.

Decreases in AIDS incidence and in the number of AIDS deaths, first noted in 1996, have been ascribed to the effect of new treatments, which prevent or delay the onset of AIDS and premature death among HIV-infected persons and result in an increase in the number of persons living with HIV and AIDS.

##### Reference

CDC. HIV surveillance report. Atlanta, GA. CDC. [published annually]. Available from: http://www.cdc.gov/hiv/topics/surveillance/resources/reports.

##### For More Information

See the NCHHSTP website at: http://www.cdc.gov/nchhstp.

### Inventory/Survey of Mental Health Organizations (IMHO/SMHO)

#### Substance Abuse and Mental Health Services Administration (SAMHSA)

##### Overview

IMHO/SMHO collected data on the number and characteristics of specialty mental health organizations in the United States.

##### Selected Content

The inventory or survey collected basic information such as type of mental health organization, ownership, number of additions and residents, and number of beds. A sample survey component was added to the inventory (IMHO) in 1998, 2000, and 2002, and the survey was renamed SMHO. The sample survey collected more detailed organization-level information from a sample of mental health organizations included in the inventory.

##### Data Years

IMHO was conducted biennially from 1986 through 1992; SMHO replaced IMHO and was conducted biennially from 1998 through 2002; IMHO was again fielded in 2004.

##### Coverage

Organizations included state psychiatric hospitals, private psychiatric hospitals, nonfederal general hospitals with separate psychiatric services, Department of Veterans Affairs medical centers, residential treatment centers for children with emotional disturbance, freestanding psychiatric outpatient clinics, freestanding partial care organizations, and multiservice (multisetting) mental health organizations not elsewhere classified.

##### Methodology

IMHO was an inventory of all mental health organizations. Its core questionnaire included one version designed for specialty mental health organizations and another for nonfederal general hospitals with separate psychiatric services. The data system was based on questionnaires mailed every other year to mental health organizations in the United States. In 1998, IMHO was replaced by SMHO. SMHO was made up of two phases. In Phase I, a full inventory of mental health organizations completed the survey by postcard, gathering a limited amount of information. From this inventory, a sample of mental health organizations was selected for Phase II, which involved completing most of the information from the IMHO core questionnaire as well as new items about managed behavioral health care.

##### Sample Size and Response Rate

In Phase I of SMHO, all organizations (about 10,000) were inventoried by postcard. A complete enumeration was needed to define the sampling frame for the sample survey. In Phase II, nonfederal general hospitals without separate mental health units, community residential organizations, and managed behavioral health care organizations were dropped from the sampling frame. From the remaining number, approximately 1,600–2,200 organizations were drawn for the sample survey and sent a questionnaire, with a response rate of approximately 90%.

##### Issues Affecting Interpretation

Revisions to definitions of mental health service providers include phasing out Community Mental Health Centers as a category after 1981–1982; increasing the number of multiservice (multisetting) mental health organizations from 1981 through 1986; increasing the number of psychiatric outpatient clinics in 1981–1982, but decreasing the number in 1983– 1984, 1986, 1990, and 1992; and increasing the number of partial care services in 1983–1984. These changes should be noted when making interyear comparisons for the affected organizations and service types. The increase in the number of nonfederal general hospitals with separate psychiatric services was partially due to a more concerted effort to identify these organizations. Forms had been sent only to those hospitals previously identified as having a separate psychiatric service. Beginning in 1980–1981, a screener form was sent to nonfederal general hospitals not previously identified as providing a separate psychiatric service, to determine whether they had such a service.

##### Reference

Center for Mental Health Services. Mental health, United States, 2004. Manderscheid RW, Berry JT, editors. HHS pub no (SMA) 06–4195. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2006. Available from: http://store.samhsa.gov/product/Mental-Health-United-States-2004/SMA06-4195.

##### For More Information

See the SAMHSA website: http://samhsa.gov.

### Medicaid Statistical Information System (MSIS)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

CMS works with its state partners to collect data on each person served by the Medicaid program, in order to monitor and evaluate access to and quality of care, trends in program eligibility, characteristics of enrollees, changes in payment policy, and other program-related issues.

##### Selected Content

Data collected include claims for services and their associated payments for each Medicaid beneficiary, by type of service. MSIS also collects information on the characteristics of every Medicaid-eligible individual, including eligibility and demographic information.

##### Data Years

Selected state data are available starting in 1992. MSIS was an optional program until 1999, when the Balanced Budget Act of 1997 mandated that all states use MSIS. Data for the 50 states and the District of Columbia are available starting in 1999.

##### Coverage

The data include information about all individuals enrolled in the Medicaid program, the services they receive, and the payments made for those services.

##### Methodology

MSIS is the primary data source for Medicaid statistical data.

It is the basic source for state-reported eligibility and claims data on the Medicaid population, its characteristics, utilization, and payments. Beginning in FY 1999, as a result of legislation enacted from the Balanced Budget Act of 1997, states were required to submit individual eligibility and claims data tapes to CMS quarterly, through MSIS. Prior to FY 1999, states were required to submit an annual HCFA–2082 report, designed to collect aggregated statistical data on eligibles, recipients, services, and expenditures during a federal fiscal year (October 1 through September 30), or, at state option, to submit eligibility data and claims through MSIS. The claims data reflect bills adjudicated or processed during the year, rather than services used during the year.

Form CMS–64, Quarterly Expense Report, a product of the financial budget and grant system, is a statement of expenditures for the Medicaid program that the states submit to CMS 30 days after each quarter. The report is an accounting statement of actual expenditures made by the states for which they are entitled to receive federal reimbursement under Title XIX for that quarter. The amount claimed on form CMS–64 is a summary of expenditures derived from source documents such as invoices, cost reports, and eligibility records. For more information, see: https://www.cms.gov/MedicaidBudgetExpendSystem/02_CMS64.asp#TopOfPage.

Form CMS–64 shows the disposition of Medicaid grant funds for the quarter being reported and for previous years, the recoupments made or refunds received, and income earned on grant funds. The data on form CMS–64 are used to reconcile the monetary advance made on the basis of states’ funding estimates filed prior to the beginning of the quarter on form CMS–37, Medicaid Program Budget Report. As such, form CMS–64 is the primary source for making adjustments for any identified overpayments and underpayments to the states. Also incorporated into this process are disallowance actions forwarded from other federal financial adjustments. Finally, form CMS–64 provides information that forms the basis for a series of Medicaid financial reports and budget analyses. Also included are third-party liability (TPL) collections tables. TPL refers to the legal obligation of certain health care sources to pay the medical claims of Medicaid recipients before Medicaid pays these claims. Medicaid pays only after the TPL sources have met their legal obligation to pay.

##### Issues Affecting Interpretation

Medicaid tables in Health, United States are based on MSIS data. Users of Medicaid data may note apparent inconsistencies in the data that are primarily due to the difference in information captured in MSIS compared with form CMS–64 reports. The most substantive difference is due to payments made to disproportionate share hospitals. Payments to disproportionate share hospitals do not appear in MSIS because states reimburse these hospitals directly and there is no fee-for-service billing. Other, less significant, differences between MSIS and form CMS–64 occur because adjudicated claims data are used in MSIS compared with actual payments reflected in form CMS–64. Differences also may occur because of internal state practices for capturing and reporting these data through two separate systems. Finally, national totals for form CMS–64 are different because they include other jurisdictions, such as the Northern Mariana Islands and American Samoa. Starting with 1999 data, MSIS excluded data from Puerto Rico and the U.S. Virgin Islands, which accounted for approximately 1 million eligibles and $250 million in Medicaid payments.

##### For More Information

See the CMS websites at: http://www.cms.hhs.gov/home/medicaid.asp and http://www.medicaid.gov/Medicaid-CHIP-Program-Information/By-Topics/Data-and-Systems/MSIS.html and the Research Data Assistance Center (ResDAC) website at: http://www.resdac.umn.edu/medicaid/data_available.asp. (Also see Appendix II, Medicaid.)

### Medical Expenditure Panel Survey (MEPS)

#### Agency for Healthcare Research and Quality (AHRQ)

##### Overview

MEPS produces nationally representative estimates of health care use, expenditures, sources of payment, insurance coverage, and quality of care for the U.S. civilian noninstitutionalized population.

##### Selected Content

MEPS data in Health, United States include total health care expenses and prescribed medicine expenses, presented by sociodemographic characteristics, type of health insurance, and sources of payment.

##### Data Years

The 1977 National Medical Care Expenditure Survey and the 1987 National Medical Expenditure Survey (NMES) are earlier versions of MEPS. Since 1996, MEPS has been conducted on an annual basis.

##### Coverage

The U.S. civilian noninstitutionalized population is the primary population represented. The 1987 and 1996 surveys also had an institutionalized population component.

##### Methodology

MEPS consists of three components: the Household Component (HC), the Medical Provider Component (MPC), and the Insurance Component (IC). MEPS–HC is a national probability survey conducted on an annual basis since 1996. The panel design of the survey features five rounds of interviewing covering two full calendar years. The HC is a nationally representative survey of the civilian noninstitutionalized population drawn from a subsample of households that participated in the prior year’s National Health Interview Survey. Whenever possible, missing expenditure data are imputed using data collected in the MPC.

The MPC collects data from hospitals, physicians, home health care providers, and pharmacies that were reported in the HC as providing care to MEPS sample persons. Data are collected in the MPC to improve the accuracy of the expenditure estimates that would be obtained if derived solely from the HC. The MPC is particularly useful in obtaining expenditure information for persons enrolled in managed care plans and Medicaid recipients. Sample sizes for the MPC vary from year to year depending on the HC sample size and the MPC sampling rates for providers.

The IC is a separate MEPS component that collects data on the types and costs of workplace health insurance from a sample of about 40,000 business establishments and 3,000 state and local governments each year.

The MEPS predecessor, the 1987 NMES, consisted of two components: the Household Survey (HS) and the Medical Provider Survey (MPS). The NMES–HS component was designed to provide nationally representative estimates of health insurance status, health insurance coverage, and health care use for the U.S. civilian noninstitutionalized population for the calendar year 1987. Data from the NMES–MPS component were used in conjunction with HS data to produce estimates of health care expenditures. The NMES–HS consisted of four rounds of household interviews. Income information was collected in a special supplement administered early in 1988. Events under the scope of the NMES–MPS included medical services provided by or under the direction of a physician, all hospital events, and home health care.

##### Sample Size and Response Rate

In recent years the MEPS annual survey has consisted of approximately 12,500 families and 32,000 individuals. The annual response rate, which reflects nonresponse to the National Health Interview Survey from which the MEPS sample is selected as well as nonresponse and attrition in MEPS, has averaged about 60% in recent years.

##### Issues Affecting Interpretation

The 1987 estimates are based on NMES, and 1996 and later years’ estimates are based on MEPS. Because expenditures in NMES were based primarily on charges, whereas those for MEPS were based on payments, data for NMES were adjusted to be more comparable with MEPS by using estimated charge-to-payment ratios for 1987. For a detailed explanation of this adjustment, see Zuvekas and Cohen (2002).

##### References

Hahn B, Lefkowitz D. Annual expenses and sources of payment for health care services. National Medical Expenditure Survey, Research Findings no 14. AHCPR pub no 93–0007. Rockville, MD. Agency for Health Care Policy and Research. 1992.
Ezzati-Rice TM, Rohde F, Greenblatt J. Sample design of the Medical Expenditure Panel Survey Household Component, 1998–2007. Methodology Report. Rockville, MD. Agency for Healthcare Research and Quality. 2008;(22). Available from: http://www.meps.ahrq.gov/mepsweb/data_files/publications/mr22/mr22.shtml.
Zuvekas SH, Cohen JW. A guide to comparing health care expenditures in the 1996 MEPS to the 1987 NMES. Inquiry. 2002;39(1):76-86. [pmid: 12067078].

##### For More Information

See the MEPS website at: http://www.meps.ahrq.gov/mepsweb/.

### Medicare Administrative Data

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

CMS collects and synthesizes Medicare enrollment, spending, and claims data to monitor and evaluate access to and quality of care, trends in utilization, changes in payment policy, and other program-related issues.

##### Selected Content

Data include claims information for services furnished to Medicare beneficiaries and Medicare enrollment data. Claims data include type of service, procedures, diagnoses, dates of service, charge amounts, and payment amounts. Enrollment data include date of birth, sex, race, ethnicity, and reason for entitlement.

##### Data Years

Some data files are available as far back as 1987, but CMS no longer provides technical support for files with data prior to 1991.

##### Coverage

Enrollment data are for all persons enrolled in the Medicare program. Claims data include data for Medicare beneficiaries who filed claims.

##### Methodology

The claims and utilization data files contain extensive utilization information at various levels of summarization for a variety of providers and services. There are many types and levels of these files: National Claims History (NCH) files, Standard Analytic files (SAFs), Medicare Provider and Analysis Review (MEDPAR) files, Medicare enrollment files, and various other files.

The NCH 100% Nearline file contains all institutional and noninstitutional claims and provides records of every Medicare claim submitted, including adjustment claims. SAFs contain final action claims data in which all adjustments have been resolved. These files contain information collected by Medicare to pay for health care services provided to a Medicare beneficiary. SAFs are available for each institutional (inpatient, outpatient, skilled nursing facility, hospice, or home health agency) and noninstitutional (physician and durable medical equipment providers) claim type. The record unit of SAFs is the claim (some episodes of care may have more than one claim). SAFs include the Inpatient SAF, the Skilled Nursing Facility SAF, the Outpatient SAF, the Home Health Agency SAF, the Hospice SAF, the Durable Medical Equipment SAF, and the Physician/Supplier SAF.

MEDPAR files contain inpatient hospital and skilled nursing facility (SNF) final action stay records. Each MEDPAR record represents a stay in an inpatient hospital or SNF. An inpatient stay record summarizes all services rendered to a beneficiary from the time of admission to a facility, through discharge. Each MEDPAR record may represent one claim or multiple claims, depending on the length of a beneficiary’s stay and the amount of inpatient services used throughout the stay.

The Denominator file contains demographic and enrollment information about each beneficiary enrolled in Medicare during a calendar year. The information in the Denominator file is frozen in March of the following calendar year. Some of the information contained in this file includes the beneficiary unique identifier, state and county codes, ZIP code, date of birth, date of death, sex, race, age, monthly entitlement indicators (for Medicare Part A, Medicare Part B, or Part A and Part B), reasons for entitlement, state buy-in indicators, and monthly managed care indicators (yes or no). The Denominator file is used to determine beneficiary demographic characteristics, entitlement, and beneficiary participation in Medicare managed care organizations (MCOs).

The Vital Status file contains demographic information about each beneficiary ever entitled to Medicare. Some of the information contained in this file includes the beneficiary unique identifier, state and county codes, ZIP code, date of birth, date of death, sex, race, and age. Often the Vital Status file is used to obtain recent death information for a cohort of Medicare beneficiaries.

The Group Health Plan (GHP) master file contains data on beneficiaries who are currently enrolled, or have ever been enrolled, in an MCO under contract with CMS. Each record represents one beneficiary, and each beneficiary has one record. Some of the information contained in this file includes the beneficiary unique identifier, date of birth, date of death, state and county, and managed care enrollment information such as dates of membership and MCO contract number. The GHP master file is used to identify the exact MCO in which beneficiaries were enrolled.

##### Issues Affecting Interpretation

Because Medicare managed care organizations might not file claims, files based only on claims data will exclude care for persons enrolled in Medicare managed care organizations. In addition, to maintain a manageable file size, some files are based on a sample of enrollees rather than on all Medicare enrollees. Coding and the interpretation of Medicare coverage rules have also changed over the life of the Medicare program.

##### For More Information

See the CMS Research Data Assistance Center (ResDAC) website at: http://www.resdac.umn.edu/medicare/index.asp and the CMS website at: http://www.cms.hhs.gov/home/medicare.asp. (Also see Appendix II, Medicare.)

### Medicare Current Beneficiary Survey (MCBS)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

MCBS produces nationally representative estimates of health status, health care use and expenditures, health insurance coverage, and socioeconomic and demographic characteristics of Medicare beneficiaries. It is used to estimate expenditures and sources of payment for all services used by Medicare beneficiaries, including copayments, deductibles, and noncovered services; to ascertain all types of health insurance coverage and relate coverage to sources of payment; and to trace processes over time, such as changes in health status and the effects of program changes.

##### Selected Content

MCBS collects data on the utilization of health services, health and functional status, health care expenditures, and health insurance and beneficiary information (such as income, living arrangement, family assistance, and quality of life).

##### Data Years

The first round of interviewing was conducted from September through December 1991, and the survey has been in the field continuously since then. The data are designed to support both cross-sectional and longitudinal analyses.

##### Coverage

MCBS is a continuous survey of a nationally representative sample of aged, institutionalized, and disabled Medicare beneficiaries.

##### Methodology

The overlapping panel design of the survey allows each sample person to be interviewed three times a year for 4 years, whether he or she resides in the community or a facility or moves between the two settings, using the version of the questionnaire appropriate to the setting. Sample persons are interviewed using computer-assisted personal interviewing (CAPI) survey instruments. Because residents of long-term care facilities often are in poor health, information about institutionalized residents is collected from proxy respondents such as nurses and other primary caregivers affiliated with the facility. The sample is selected from the Medicare enrollment files, with oversampling among disabled persons under 65 years of age and among persons 80 years of age and over.

MCBS has two components: the Cost and Use file and the Access to Care file. Medicare claims are linked to survey-reported events to produce the Cost and Use file, which provides complete expenditure and source-of-payment data on all health care services, including those not covered by Medicare. The Access to Care file contains information on beneficiaries’ access to health care, satisfaction with care, and usual source of care. The sample for this file represents the always enrolled population—those who participated in the Medicare program for the entire year. In contrast, the Cost and Use file represents the ever enrolled population, including those who entered Medicare and those who died during the year.

##### Sample Size and Response Rate

Each fall, about one-third of the sample is retired and roughly 6,000 new sample persons are included in the survey; the exact number chosen is based on projections of target samples of 12,000 persons with 3 years of cost and use information distributed appropriately across the sample cells. In the community, response rates for initial interviews range in the mid- to high 80s; once respondents have completed the first interview, their participation in subsequent rounds is 95% or more. In recent rounds, data have been collected from approximately 16,000 beneficiaries. Roughly 90% of the sample is made up of persons who live in the community, with the remaining persons living in long-term care facilities. Response rates for facility interviews approach 100%.

##### Issues Affecting Interpretation

Because only Medicare enrollees are included in MCBS, the survey excludes a small proportion of persons 65 years of age and over who are not enrolled in Medicare. This should be noted when using MCBS to make estimates of the entire population 65 years of age and over in the United States.

##### References

Adler GS. A profile of the Medicare Current Beneficiary Survey. Health Care Financ Rev. 1994;15(4):153-63. [pmid: 10138483].
Lo A, Chu A, Apodaca R. Redesign of the Medicare Current Beneficiary Survey sample. Rockville, MD. Westat, Inc. 2003. Available from: http://www.amstat.org/sections/srms/Proceedings/y2002/Files/JSM2002-000662.pdf.

##### For More Information

See the MCBS website at: http://www.cms.hhs.gov/MCBS.

### Monitoring the Future (MTF) Study

#### National Institute on Drug Abuse (NIDA)

##### Overview

MTF is an ongoing study of the behaviors, attitudes, and values of U.S. secondary school students, college students, and young adults.

##### Selected Content

Data collected include lifetime, annual, and 30-day prevalence of use of specific illegal drugs and substances, inhalants, tobacco, and alcohol. Data are also collected on usage levels, frequency of use, perceived risks associated with use, opinions about whether use is approved or disapproved by others, and opinions about availability of the substances.

##### Data Years

MTF has been conducted annually since 1975, initially with high school seniors. Ongoing panel studies of representative samples from each graduating class have been conducted by mail since 1976, and annual surveys of 8th and 10th graders were initiated in 1991.

##### Coverage

MTF surveys a sample of high school seniors, 10th graders, and 8th graders selected to be representative of all seniors, 10th graders, and 8th graders in public and private high schools in the coterminous United States. Annual follow-up questionnaires are mailed to a sample of each graduating class for a number of years after their initial participation to gather information on college students and young adults.

##### Methodology

The survey design is a multistage random sample, with stage 1 the selection of particular geographic areas, stage 2 the selection of one or more schools in each area, and stage 3 the selection of students within each school. Data are collected using self-administered questionnaires conducted in the classroom by representatives of the University of Michigan’s Institute for Social Research. Dropouts and students who are absent on the day of the survey are excluded. Recognizing that the dropout population is at higher risk for drug use, MTF was expanded in 1991 to include similar nationally representative samples of 8th and 10th graders, who have lower dropout rates than seniors and include future high-risk 12th grade dropouts. For more information on MTF adjustments for absentees and dropouts, see Johnston et al. (2011, vol 1).

##### Sample Size and Response Rate

In 2010, a total of 46,482 students in the 8th, 10th, and 12th grades in 396 secondary schools were surveyed. The annual senior samples comprised 15,127 seniors in 126 public and private high schools nationwide. The 10th-grade samples involved 15,586 students in 123 schools, and the 8th-grade samples had 15,769 students in 147 schools. Response rates were 85% for 12th graders, 87% for 10th graders, and 88% for 8th graders and have been relatively constant across time. Absentees constitute virtually all of the nonresponding students.

##### Issues Affecting Interpretation

Estimates of substance use among youth based on the National Survey on Drug Use & Health (NSDUH) are not directly comparable with estimates based on MTF and the Youth Risk Behavior Survey (YRBS). In addition to the fact that MTF excludes dropouts and absentees, rates are not directly comparable across these surveys because of differences in populations covered, sample design, questionnaires, and interview setting. NSDUH collects data in residences, whereas MTF and YRBS collect data in school classrooms. In addition, NSDUH estimates are tabulated by age, whereas MTF and YRBS estimates are tabulated by grade, representing different ages as well as different populations.

##### References

Johnston LD, O’Malley PM, Bachman JG, Schulenberg JE. Monitoring the Future: National survey results on drug use, 1975–2010. Secondary school students. Ann Arbor, MI. Institute for Social Research, The University of Michigan. 2011;I. Available from: http://www.monitoringthefuture.org/pubs/monographs/mtf-vol1_2010.pdf.
Johnston LD, O’Malley PM, Bachman JG, Schulenberg JE. Monitoring the Future: National results on adolescent drug use. Overview of key findings, 2010. Ann Arbor, MI. Institute for Social Research, The University of Michigan. 2011. Available from: http://www.monitoringthefuture.org/pubs/monographs/mtf-overview2010.pdf.
Cowan CD. Coverage, sample design, and weighting in three federal surveys. J Drug Issues. 2001;31(3):599-614.

##### For More Information

See the NIDA website at: http://www.nida.nih.gov/Infofax/HSYouthtrends.html and the MTF website at: http://www.monitoringthefuture.org.

### National Ambulatory Medical Care Survey (NAMCS)

#### CDC/NCHS

##### Overview

NAMCS is a national survey designed to provide information about the provision and use of medical care services in office-based physician practices in the United States.

##### Selected Content

Data are collected from medical records on type of providers seen; reason for visit; diagnoses; drugs ordered, provided, or continued; and selected procedures and tests ordered or performed during the visit. Patient data include age, sex, race, and expected source of payment. Data are also collected on selected characteristics of physician practices.

##### Data Years

NAMCS, which began in 1973, was conducted annually until 1981, once in 1985, and resumed an annual schedule in 1989.

##### Coverage

The scope of the survey covers patient encounters in the offices of nonfederally-employed physicians classified by the American Medical Association (AMA) or American Osteopathic Association (AOA) as office-based patient care physicians. Patient encounters with physicians engaged in prepaid practices [health maintenance organizations (HMOs), independent practice organizations (IPAs), and other prepaid practices] are included in NAMCS. Excluded are visits to hospital-based physicians; visits to specialists in anesthesiology, pathology, or radiology; and visits to physicians who are principally engaged in teaching, research, or administration. Telephone contacts and nonoffice visits are also excluded. Starting in 2006, NAMCS includes visits to a separate sample of community health centers (CHCs).

##### Methodology

A multistage probability design is employed. The first-stage sample consisted of 84 primary sampling units (PSUs) in 1985, and beginning in 1989, 112 PSUs, which were selected from about 1,900 such units into which the United States had been divided. In each sample PSU, a sample of practicing nonfederal office-based physicians is selected from master files maintained by AMA and AOA. The final stage involves systematic random samples of office visits during randomly assigned 7-day reporting periods. In 1985, the survey excluded Alaska and Hawaii. Starting in 1989, the survey included all 50 states and the District of Columbia.

Starting in 2006, a dual-sampling procedure was used to select CHC physicians and nonphysician clinicians. First, the traditional NAMCS sample was selected using the methods described above. Second, information from the Health Resources and Services Administration and the Indian Health Service was used to select a sample of CHCs. Within CHCs, a maximum of three health care providers were selected, including physicians, physician assistants, nurse practitioners, or nurse midwives. After selection, CHC providers followed traditional NAMCS methods for selecting patient visits.

The U.S. Census Bureau acts as the data collection agent for NAMCS. Screening interviews are conducted by Census field representatives to obtain information about physicians’ office-based practices and to ensure that the practice is within the scope of the survey. Field representatives visit eligible physicians prior to their participation in the survey to provide them with survey materials and instruct them on how to sample patient visits and complete patient record forms. Participants are asked to complete forms for a systematic random sample of approximately 30 office visits occurring during a randomly assigned 1-week period, but increasingly patient record forms are abstracted by field representatives.

Sample data are weighted to produce national estimates. The estimation procedure used in NAMCS has three basic components: inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and ratio adjustment to fixed totals.

##### Sample Size and Response Rate

In each sample year from 2003 through 2005, 3,000 physicians were sampled and the response rates were 66%–70%. Data were provided for approximately 25,000 visits per survey year. In sample years 2006 and 2007, 3,500 physicians were sampled and the response rates were 64%–65%. Data were provided for approximately 29,000 visits in 2006 and almost 33,000 visits in 2007. In 2008, a sample of 3,319 physicians was selected: 2,229 were in-scope and 1,334 participated, for a response rate of 59%. Data were provided for 28,741 visits. In 2009, a sample of 3,319 physicians was selected: 2,290 were in-scope and 1,445 participated, for a response rate of 62%. Data were provided for 32,281 visits. The response rates have been modified to accommodate the mixture of one- and two-stage samples of providers.

##### Issues Affecting Interpretation

The NAMCS patient record form is modified approximately every 2–4 years to reflect changes in physician practice characteristics, patterns of care, and technological innovations. Examples of recent changes include increasing the number of drugs recorded on the patient record form and adding checkboxes for specific tests or procedures performed. Sample sizes vary by survey year. For some years it is suggested that analysts combine two or more years of data if they wish to examine relatively rare populations or events. Starting with Health, United States, 2005, data for survey years 2001–2002 were revised to be consistent with the weighting scheme introduced in the 2003 NAMCS data. For more information on the new weighting scheme, see Hing et al. (2005).

##### Reference

Hing E, Cherry DK, Woodwell DA. National Ambulatory Medical Care Survey: 2003 summary. Advance data from vital and health statistics. Hyattsville, MD. NCHS. 2005;(365). Available from: http://www.cdc.gov/nchs/data/ad/ad365.pdf.

##### For More Information

See the National Health Care Surveys website at: http://www.cdc.gov/nchs/dhcs.htm and the Ambulatory Health Care Data website at: http://www.cdc.gov/nchs/ahcd.htm.

### National Compensation Survey (NCS)

#### Bureau of Labor Statistics (BLS)

##### Overview

NCS provides comprehensive measures of occupational earnings, compensation cost trends, benefit incidence, and detailed plan provisions.

##### Selected Content

Detailed occupational earnings are collected for metropolitan and nonmetropolitan areas, for broad geographic regions, and on a national basis. The Employment Cost Index (ECI) and Employer Costs for Employee Compensation (ECEC) are compensation measures derived from NCS. ECI measures changes in labor costs; average hourly employer costs for employee compensation are presented in ECEC. National benefits data are presented for five broad occupational groupings: management, professional, and related; sales and office; service; natural resources, construction, and maintenance; and production, transportation, and material moving. Data are also available by goods-and service-producing industries, union affiliation, and establishment size.

##### Data Years

NCS replaces three existing BLS surveys: ECI, the Occupational Compensation Survey Program (OCSP), and the Employee Benefits Survey (EBS). ECI and EBS were fully integrated into NCS in 1999. Prior to 1999, EBS was collected for small private establishments (those employing fewer than 100 workers) and from state and local governments regardless of employment size. In odd-numbered years, data were collected for medium and large private establishments (those employing 100 workers or more). ECI was created in the mid-1970s, and EBS was added to an existing data collection effort (the Professional, Administrative and Technical Pay Survey) in the late 1970s. ECEC was developed in 1987.

##### Coverage

NCS provides information for the Nation for the nine census divisions and for 152 selected areas (combined statistical areas, metropolitan statistical areas, micropolitan statistical areas, and county clusters). Not all areas have information for all occupations. NCS includes both full- and part-time workers who are paid a wage or salary and includes data for the civilian economy, including both private industry and state and local government. It excludes agriculture, fishing, and forestry industries; private household workers; and the federal government.

##### Methodology

NCS is conducted quarterly by the BLS’ Office of Compensation and Working Conditions. The sample is selected using a three-stage design. The first stage involves the selection of areas for the state and local government sample and the private industry sample. In the second stage, establishments are selected systematically, with the probability of selection proportionate to their relative employment size within the industry. Use of this technique means that the larger an establishment’s employment, the greater its chance of selection. The third stage of sampling is a probability sample of occupations within a sampled establishment. This step is performed by the BLS field economist during an interview with the respondent establishment in which selection of an occupation is based on probability of selection proportionate to employment in the establishment, and each occupation is classified under its corresponding major occupational group.

Data collection is conducted by BLS field economists. Data are gathered from each establishment on the primary business activity of the establishment; types of occupations; number of employees; wages, salaries, and benefits; hours of work; and duties and responsibilities. Wage data obtained by occupation and work level allow NCS to publish occupational wage statistics for localities, census divisions, and the Nation.

##### Sample Size and Response Rate

The sample consists of approximately 152 areas that represent the Nation’s almost 370 metropolitan statistical areas and almost 580 micropolitan statistical areas, as defined by the Office of Management and Budget (OMB), and the remaining portions of the 50 states. NCS is in the midst of a 6-year transition from the OMB’s December 1993 area definitions to the December 2003 area definitions. During this transition, NCS is surveying additional areas while new areas are being phased into the sample and others are being phased out. For more information, see: http://www.bls.gov/ncs/ncswage2007.htm#AppendixA.

##### Issues Affecting Interpretation

Because NCS merges separate surveys, trend analyses prior to 2000 should be interpreted with care. The industrial coverage, establishment size coverage, and geographic coverage for EBS have changed since 1990. All surveys conducted from 1979 through 1989 excluded part-time employees, as well as establishments in Alaska and Hawaii. The surveys conducted from 1979 through 1986 covered only medium and large private establishments and excluded most of the service industries. Establishments that employed at least 50, 100, or 250 workers (depending on the industry) were included. The survey conducted in 1987 consisted of state and local governments with 50 or more employees. The surveys carried out in 1988 and 1989 included all private-sector establishments that employed 100 or more people.

ECEC switched to new industry and occupation classification systems with the release of the March 2004 data. The North American Industry Classification System (NAICS) is now used to classify industries, and the 2000 Standard Occupational Classification (SOC) system is used to classify occupations. ECEC data based on the 1987 Standard Industrial Classification System and the 1990 Occupational Classification System are no longer produced, and data classified under these coding schemes are not comparable with data classified under NAICS or SOC. The 2007 NAICS is gradually replacing the 2002 NAICS, but this does not affect trends. Beginning with the March 2004 quarter, historical data are available based on NAICS and the 2000 SOC. The historical tables are available from: http://www.bls.gov/ncs/ect/home.htm or upon request from BLS. For more detailed information on NAICS and SOC, including background definitions and implementation schedules, see the BLS websites at: http://www.bls.gov/bls/naics.htm and http://www.bls.gov/soc/home.htm.

The state and local government sample, which is replaced less frequently than the private industry sample, was replaced in its entirety in September 2007. As a result of this replacement, the number of state and local government occupations and establishments increased substantially. The private industry sample is rotated over approximately 5 years, which makes the sample more representative of the economy and reduces respondent burden. Data are collected for the pay period including the 12th day of the survey months of March, June, September, and December. The sample is replaced on a cross-area, cross-industry basis.

##### References

Bureau of Labor Statistics. Employer costs for employee compensation—March 2011. [press release USDL–11–0849]. Washington, DC. U.S. Department of Labor. 2011. June. 8. Available from: http://www.bls.gov/news.release/archives/ecec_06082011.pdf.
Wiatrowski WJ. The National Compensation Survey: Compensation statistics for the 21st century. Washington, DC. US Department of Labor, Bureau of Labor Statistics. Compensation and Working Conditions (CWC) Online 2000. Winter. 5-14. Available from: http://www.bls.gov/opub/cwc/archive/winter2000art1.pdf.
U.S. Bureau of Labor Statistics. BLS handbook of methods. National compensation measures. 2007;ch 8. Available from: http://www.bls.gov/opub/hom/pdf/homch8.pdf.

##### For More Information

See the NCS website at: http://www.bls.gov/ncs.

### National Expenditures for Mental Health Services and Substance Abuse Treatment

#### Substance Abuse and Mental Health Services Administration (SAMHSA)

##### Overview

National Expenditures for Mental Health Services and Substance Abuse Treatment estimates track spending on health care services related to the diagnosis and treatment of mental and substance use disorders in the United States.

##### Selected Content

The estimates focus on expenditures for the diagnosis and treatment of mental health (MH) and substance abuse (SA) disorders, and of both disorders combined (MHSA). Multiple years of comparable data are available so that estimates can be examined over time. MHSA estimates were designed to be consistent with the National Health Expenditure Accounts (NHEA) so that they can also be compared with expenditure data on all health care services. MHSA expenditure data are available by the types of services delivered (provider type and type of care) and by who pays for those services (payers).

Providers are identified by the major types of services they deliver and often furnish the data used to estimate spending. Service providers and products include all hospitals (general, specialty, and nonspecialty); all physicians (psychiatrists and nonpsychiatrists); other behavioral health professionals; free-standing nursing homes; free-standing home health care agencies; other personal and public health, specialty MH, and SA centers; and retail prescription drugs. Payer categories include private sources (i.e., out-of-pocket and private insurance) and public sources including Medicare, Medicaid, and other federal-, state-, and local-level sources.

##### Data Years

The first report on MHSA expenditure estimates was published in 1998 and described estimates for 1986–1996. The most recent report, published in 2011, described data for 1986–2005.

##### Methodology

MHSA expenditure estimates integrate a wealth of national data sets from various government agencies and private organizations. MHSA spending estimates were constructed for two major treatment categories of spending—MH and SA—with SA estimated in two separate subcategories: alcohol abuse (AA) and drug abuse (DA). Spending for services is based solely on the primary diagnosis and does not include spending associated with a secondary diagnosis. Costs not directly related to treatment are excluded. Expenditures for issues that result from MH and SA (e.g., liver disease) are also excluded.

Spending proportions for MH, AA, and DA were calculated by multiplying utilization by average prices (accounting for discounts and cost sharing) for each diagnostic group and dividing by the sum of all groups. These proportions were applied to the appropriate national health expenditure estimates from the NHEA to estimate MH, AA, and DA national spending. SA expenditures were summed from AA and DA estimates. These estimations were made within the type of payer and provider. Expenditures by provider and payer are further divided into inpatient, outpatient, and residential care.

MHSA expenditure data are also presented by grouping specialty providers from specialty institutions. These estimates were drawn from facility surveys (facility-level reporting). Total revenues were reported in these specialty surveys by facility and by payment source. Many of these data come from specialty provider inventories and surveys sponsored by SAMHSA, such as the Inventory/Survey of Mental Health Organizations (IMHO/SMHO) and the National Survey of Substance Abuse Treatment Services. Data for all other providers come from administrative claims data and surveys that collect encounter-level or patient-level data. In some cases, these surveys sampled a first stage of providers and then a second stage of encounters between providers and patients. With characteristics on each encounter or patient, expenditures for specific diagnoses such as MH, SA, or all health care were calculated.

Estimates for non-MHSA specialty facilities were carved out of estimates of total national health services and supplies expenditures developed by CMS. Spending for specialty and nonspecialty facilities were summed (after duplicates between SAMHSA and CMS data were removed) to obtain national data for total MHSA expenditures. As a final check of the estimates, MHSA dollars were compared with all personal and government public health expenditures.

The remaining two categories of spending—retail purchases of prescription drugs and insurance administration—are not given a specialty or nonspecialty designation.

Spending for MH and SA services is defined using diagnostic codes from the International Classification of Diseases, 9th Revision, Clinical Modification (ICD–9–CM) for mental disorders (sections 290–319). A subset of these disorders, including various types of dementia, Alzheimer’s disease, nondependent use of drugs, tobacco abuse disorder, delays in development, and mental retardation, are not included in the analysis.

##### Issues Affecting Interpretation

Estimates were prepared using standard estimation techniques and the best available survey information. They represent the only MHSA estimates comparable with total health care spending in the United States. Multiple data sources were used to piece together and cross-check information that ultimately formed the basis for the estimates, and each of those data sources has its own strengths and weaknesses. Estimates that were reported previously should not be combined with the most recent estimates (1986–2005) because data are revised over time and estimates have been updated to include better data sources and improved methods.

##### Reference

Substance Abuse and Mental Health Services Administration (SAMHSA). National expenditures for mental health services and substance abuse treatment, 1986–2005. HHS pub no (SMA) 10–4612. Rockville, MD. Center for Mental Health Services and Center for Substance Abuse Treatment, SAMHSA. 2011. Available from: http://store.samhsa.gov/product/National-Expenditures-for-Mental-Health-Services-and-Substance-Abuse-Treatment-1986-2005/SMA10-4612.

### National Health Expenditure Accounts (NHEA)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

NHEA provide estimates of spending on different types of health care goods and services in the United States, and the programs and payers that purchase those goods and services.

##### Selected Content

NHEA contain all of the main components of the health care system within a unified, mutually exclusive and exhaustive structure. The accounts measure spending for health care in the United States by type of service delivered (e.g., hospital care, physician and clinical services, nursing home care) and source of funding for those services (e.g., private health insurance, Medicare, Medicaid, out-of-pocket). A common set of definitions are applied to the types of services delivered, and to the source of funding for those services, that allow for comparisons over time.

##### Data Years

Expenditure estimates are available starting in 1960 in data files or published articles. In 1964, the U.S. Department of Health and Human Services began publishing these data annually.

##### Methodology

The primary sources for estimates related to hospital care spending were the American Hospital Association (AHA) data on hospital finances and the U.S. Census Bureau’s Services Annual Survey (SAS) and Quarterly Services Survey (QSS). These were supplemented by data on federal hospitals. The salaries of physicians and dentists on the staffs of hospitals, hospital outpatient clinics, hospital-based home health care agencies, and nursing home care provided in the hospital setting were also considered to be components of hospital care. Expenditures for physician and clinical services, nursing care facilities and continuing care retirement communities, home health care, dentists, and the services of health care professionals (e.g., chiropractors, private duty nurses, therapists, and podiatrists) were estimated primarily by using a combination of data from SAS and the U.S. Census Bureau’s quinquennial Economic Census. Spending between Economic Census years of data were interpolated using data from SAS.

The estimates of retail spending for prescription drugs were based on industry data on prescription drug transactions from the U.S. Census Bureau’s Census of Retail Trade and IMS Health, an organization that collects data from the pharmaceutical industry. Final merchandise line sales from the 2007 Economic Census of the retail sector were incorporated into the prescription drug estimates in 2009.

Expenditures for other medical nondurables and for vision products and other medical durables purchased in retail outlets were based on input-output (I/O) tables and personal consumption expenditure tables prepared by the U.S. Department of Commerce’s Bureau of Economic Analysis, U.S. Bureau of Labor Statistics’ (BLS) Consumer Expenditure Survey, Kline and Co. Annual Survey of Over-the-Counter Drugs, and the 1987 National Medical Expenditure Survey and the Medical Expenditure Panel Surveys (MEPS) conducted by the Agency for Healthcare Research and Quality (AHRQ). Those durable and nondurable products provided to inpatients in hospitals or nursing homes, and those provided by licensed professionals or through home health care agencies, were excluded here but are included with the expenditure estimates for the provider service category.

The Structures and Equipment component of NHEA included estimates that measure the value of new construction put in place by the medical sector, and includes buildings—mainly hospitals and nursing homes. From 1993 through 2008, the primary source for these Private Structures estimates was the Annual Capital Expenditures Survey conducted by the Census Bureau. The 2009 Private Structures estimate was extrapolated forward from 2008 using data from the C–30 survey of new construction. The estimates for preceding years were developed using data published by the Census Bureau and the Bureau of Economic Analysis. Public structures data were based on information published by the Bureau of Economic Analysis. Medical Capital Equipment comprised the value of new capital equipment (including software) purchased or put in place by the medical sector during the year. For Private Equipment, the estimates were derived using a variety of data published by the Census Bureau, as well as data published by the Bureau of Economic Analysis. The Public Equipment estimates were based on data published by the Bureau of Economic Analysis.

Expenditures for noncommercial research (the cost of commercial research by drug companies was assumed to be embedded in the price charged for the product and therefore was not counted again) were included in the Investment category and were developed from information gathered by the National Institutes of Health and the National Science Foundation.

Source-of-funding estimates come from many sources. Private health insurance benefits by type of service were estimated using provider survey data in conjunction with source-of-funding spending from several sources. These sources included the U.S. Census Bureau, the American Medical Association (AMA), AHA, and IMS Health, as well as household data from surveys such as the National Medical Care Expenditure Survey (National Center for Health Services Research, 1987) and later, MEPS (AHRQ, 1996–2006 and 2009).

Data on federal health care programs (e.g., Medicare, Medicaid, and CHIP) were taken from administrative records maintained by the servicing agencies. Among the sources used to estimate state and local government spending for health care were the U.S. Census Bureau’s Government Finances reports and the National Academy of Social Insurance reports on state-operated workers’ compensation programs. Federal, state, and local expenditures for education and training of medical personnel were excluded from these measures where they were separable. Data on the financial experience of health insurance organizations came from CMS analyses of A.M. Best Company (Oldwik, NJ) private health insurance data reported to the National Association of Insurance Commissioners, from the BLS survey on the cost of employer-sponsored health insurance and consumer expenditures, and from MEPS data for the self-insured.

Information on out-of-pocket spending from the U.S. Census Bureau’s SAS; BLS’ Consumer Expenditure Survey; the 1987 National Medical Care Expenditure Survey and MEPS; and from private surveys conducted by AHA, AMA, the American Dental Association, and IMS Health was used to develop estimates of direct spending by consumers.

##### Issues Affecting Interpretation

Every 5 years, NHEA undergo a comprehensive revision that includes the incorporation of newly available source data, methodological and definitional changes, and benchmark estimates from the Economic Census.

During these comprehensive revisions, the entire NHEA time series is opened for revision. In addition to these changes, during the 2009 comprehensive revision, the classification structure of NHEA was changed to more clearly align programs and payers with the current health care system.

##### References

Martin A, Lassman D, Whittle L, Catlin A. National Health Expenditure Accounts Team. Recession contributes to slowest annual rate of increase in health spending in five decades. Health Aff (Millwood). 2011;30(1):11-22. [pmid: 21209433].
Centers for Medicare & Medicaid Services (CMS). National Health Expenditure Accounts: Methodology Paper, 2010: Definitions, Sources, and Methods. Baltimore, MD. CMS. 2011. Available from: https://www.cms.gov/NationalHealthExpendData/downloads/dsm-10.pdf.
Centers for Medicare & Medicaid Services (CMS). Summary of National Health Expenditure Account 2009 comprehensive revisions. Baltimore, MD. CMS. 2010. Available from: http://www.cms.gov/NationalHealthExpendData/downloads/benchmark2009.pdf.

##### For More Information

See the CMS National Health Expenditure Accounts website at: http://www.cms.hhs.gov/NationalHealthExpendData.

### National Health and Nutrition Examination Survey (NHANES)

#### CDC/NCHS

##### Overview

The NHANES program includes a series of cross-sectional, nationally representative health examination surveys conducted in mobile examination units or clinics (MECs). In the first series of surveys, the National Health Examination Survey (NHES), data were collected on the prevalence of certain chronic diseases, the distributions of various physical and psychological measures, and measures of growth and development. In 1971, a nutrition surveillance component was added, and the survey name was changed to NHANES. See the Data Years section for more information on the survey name and the years it was conducted.

##### Selected Content

NHANES has collected data on chronic disease prevalence and conditions (including undiagnosed conditions) and on risk factors such as obesity and smoking, elevated serum cholesterol levels, hypertension, diet and nutritional status, immunization status, infectious disease prevalence, health insurance, and measures of environmental exposures. Other topics addressed include hearing, vision, mental health, anemia, diabetes, cardiovascular disease, osteoporosis, oral health, pharmaceuticals and dietary supplements used, and physical fitness.

NHES I data were collected on the prevalence of certain chronic diseases, as well as the distribution of various physical and psychological measures, including blood pressure and serum cholesterol levels. NHES II and NHES III focused on factors related to growth and development in children and youth.

For NHANES I, data were collected on indicators of the nutritional and health status of the American people through dietary intake data, biochemical tests, physical measurements, and clinical assessments for evidence of nutritional deficiency. Detailed examinations were conducted by dentists, ophthalmologists, and dermatologists, with an assessment of need for treatment. In addition, data were obtained for a subsample of adults on overall health care needs and behavior, and more detailed examination data were collected on cardiovascular, respiratory, arthritic, and hearing conditions. For NHANES II, the nutrition component was expanded and the medical area focused on diabetes, kidney and liver function, allergy, and speech pathology. The third survey (NHANES III) additionally included data on antibodies, spirometry, and bone health.

Beginning in 1999 with continuous data collection for NHANES, new topics have included cardiorespiratory fitness, physical functioning, lower extremity disease, full body scan (DXA) for body fat and bone density, and tuberculosis infection.

##### Data Years

Data have been collected from surveys conducted during 1960–1962 (NHES I), 1963–1965 (NHES II), 1966–1970 (NHES III), 1971–1974 (NHANES I), 1976–1980 (NHANES II), 1982–1984 Hispanic Health and Nutrition Examination Survey (HHANES), and 1988–1994 (NHANES III). Beginning in 1999, the survey has been conducted continuously.

##### Coverage

With the exception of HHANES (see Methodology, below), NHES and NHANES provide estimates of the health status of the civilian noninstitutionalized population of the United States. NHES II and NHES III examined probability samples of the Nation’s noninstitutionalized children 6–11 and 12–17 years of age, respectively.

The NHANES I target population was the civilian noninstitutionalized population 1–74 years of age residing in the coterminous United States, except for people residing on any of the reservation lands set aside for the use of American Indians.

The NHANES II target population was the civilian noninstitutionalized population 6 months to 74 years of age residing in the United States, including Alaska and Hawaii.

HHANES studied three geographically and ethnically distinct populations: Mexican Americans living in Texas, New Mexico, Arizona, Colorado, and California; Cuban Americans living in Dade County, Florida; and Puerto Ricans living in parts of New York, New Jersey, and Connecticut.

The NHANES III target population was the civilian noninstitutionalized population 2 months of age and over. The sample design provided for oversampling among children 2 months to 5 years of age, persons 60 years of age and over, black persons, and persons of Mexican origin.

Beginning in 1999, NHANES oversampled low-income persons, adolescents 12–19 years of age, persons 60 years of age and over, African Americans, and persons of Mexican origin. The sample for data years 1999–2006 is not designed to give a nationally representative sample for the total population of Hispanics residing in the United States. Starting with 2007–2008 data collection, all Hispanic persons were oversampled, not just Mexican American persons. For more information on the sampling methodology changes, see: http://www.cdc.gov/nchs/nhanes/nhanes2007-2008/sampling_0708.htm.

##### Methodology

NHANES include clinical examinations, selected medical and laboratory tests, and self-reported data. NHANES and previous surveys interviewed persons in their homes and conducted medical examinations, including laboratory analysis of blood, urine, and other tissue samples. Medical examinations and laboratory tests follow very specific protocols and are as standard as possible to ensure comparability across sites and providers. In 1999–2002, as a substitute for the MEC examinations, a small number of survey participants received an abbreviated health examination in their homes if they were unable to come to the MEC.

For the first program or cycle of NHES I, a highly stratified multistage probability sample was selected to represent the 111 million civilian noninstitutionalized adults 18–79 years of age in the United States at that time. The sample areas consisted of 42 primary sampling units (PSUs) from 1,900 geographic units. NHES II and NHES III were also multistage stratified probability samples of clusters of households in land-based segments. NHES II and III used the same 40 PSUs.

For NHANES I, the sample areas consisted of 65 PSUs. A subsample of persons 25–74 years of age was selected to receive the more detailed health examination. Groups at high risk of malnutrition were oversampled.

NHANES II used a multistage probability design that involved selection of PSUs, segments (clusters of households) within PSUs, households, eligible persons, and finally, sample persons. The sample design provided for oversampling among persons 6 months to 5 years of age, 60–74 years of age, and those living in poverty areas.

HHANES was similar in content and design to NHANES I and II. The major difference between HHANES and the previous national surveys is that HHANES used a probability sample of three special subgroups of the population living in selected areas of the United States, rather than a national probability sample. The three HHANES universes included approximately 84%, 57%, and 59%, respectively, of the 1980 Mexican-, Cuban-, and Puerto Rican-origin populations in the continental United States.

The survey for NHANES III was conducted from 1988 to 1994 and consisted of two phases of equal length and sample size. Phases 1 and 2 comprised random samples of the civilian U.S. population living in households. About 40,000 persons 2 months of age and over were selected and asked to complete an extensive interview and an examination. Participants were selected from households in 81 counties across the United States. Children 2 months to 5 years of age and persons 60 years of age and over were oversampled to provide precise descriptive information on the health status of selected population groups in the United States.

Beginning in 1999, NHANES became a continuous, annual survey, which allows increased flexibility in survey content. Since April 1999, NHANES has collected data every year from a representative sample of the civilian noninstitutionalized U.S. population, newborns and older, by in-home personal interviews and physical examinations in the MEC. The sample design is a complex, multistage, clustered design using unequal probabilities of selection. The first-stage sample frame for continuous NHANES during 1999–2001 was the list of PSUs selected for the design of the National Health Interview Survey. Typically, an NHANES PSU is a county. For 2002, an independent sample of PSUs (based on current census data) was selected. This independent design was used for the period 2002–2010. For 1999, because of a delay in the start of data collection, 12 distinct PSUs were in the annual sample. For each year in 2000–2010, 15 PSUs were selected. The within-PSU design involves forming secondary sampling units that are nested within census tracts, selecting dwelling units within secondary units, and then selecting sample persons within dwelling units. The final sample person selection involves differential probabilities of selection according to the demographic variables of sex (male or female), race and ethnicity (Hispanic, black, or all other persons), and age. Because of the differential probabilities of selection, dwelling units are screened for potential sample persons. Sample weights are available and should be used in estimating descriptive statistics. The complex design features should be used in estimating standard errors for the descriptive estimates.

The estimation procedure used to produce national statistics for all NHANES involved inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and poststratified ratio adjustment to population totals. Sampling errors also were estimated, to measure the reliability of the statistics.

##### Sample Size and Response Rate

NHES I sampled 7,710 adults. The examination response rate was 87%. NHES II sampled 7,417 children and reported a response rate of 96% for the questionnaire sample and 73% for the examination sample. NHES III sampled 7,514 youth and reported a response rate of 90%.

A sample of 28,043 persons was selected for NHANES I. Household interviews were completed for more than 96% of the persons selected, and about 75% (20,749) were examined. A sample of 27,801 persons was selected for NHANES II, and 73% (20,322) were examined.

In HHANES, 9,894 persons in the Southwest were selected (75%, or 7,462, were examined); in Dade County, 2,244 persons were selected (60%, or 1,357, were examined); and in the Northeast, 3,786 persons were selected (75%, or 2,834, were examined). Over the 6-year survey period of NHANES III, 39,695 persons were selected, the household interview response rate was 86%, and the medical examination response rate was 78%.

In the sample selection for NHANES 1999–2000, there were 22,839 dwelling units screened. Of these, 6,005 households had at least one eligible sample person identified for interviewing, for a total of 12,160 eligible sample persons. The overall response rate in NHANES 1999–2000 for those interviewed was 82% (9,965 of 12,160), and the response rate for those examined was 76% (9,282 of 12,160). For NHANES 2001–2002, there were 13,156 persons selected in the sample, of which 84% (11,039) were interviewed and 80% (10,480) completed the health examination component of the survey. For NHANES 2003–2004, 6,410 households had at least one eligible sample person identified for interviewing. A total of 12,761 eligible sample persons were identified, of which 79% (10,115) were interviewed and 76% (9,653) completed the health examination component. For NHANES 2005–2006, a total of 12,862 persons were identified, of which 80% (10,348) were interviewed and 77% (9,950) completed the health examination component. For NHANES 2007–2008, a total of 12,943 persons were identified, of which 78% (10,149) were interviewed and 75% (9,762) completed the health examination component. For NHANES 2009–2010, a total of 13,272 persons were identified, of which 79% (10,537) were interviewed and 77% (10,253) completed the health examination component. For more information on unweighted NHANES response rates and response weights using sample size weighted to Current Population Survey population totals, see: http://www.cdc.gov/nchs/nhanes/response_rates_CPS.htm.

##### Issues Affecting Interpretation

Data elements, laboratory tests performed, and the technological sophistication of medical examination and laboratory equipment have changed over time. Therefore, trend analyses should carefully examine how specific data elements were collected across the various NHES and NHANES surveys. Data files are revised periodically. If the file changes are minor and the impact on estimates small, then the data are not revised in Health, United States. Major data changes are incorporated.

##### References

Gordon T, Miller HW. Cycle I of the Health Examination Survey: Sample and response, United States, 1960–1962. Vital Health Stat. Hyattsville, MD. NCHS. 1974;11(1). Available from: http://www.cdc.gov/nchs/data/series/sr_11/sr11_001.pdf.
NCHS. Plan, operation, and response results of a program of children’s examinations. Vital Health Stat. Hyattsville, MD. NCHS. 1967;1(5). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_005.pdf.
Schaible WL. Quality control in a National Health Examination Survey. Vital Health Stat. Hyattsville, MD. NCHS. 1973;2(44). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_044.pdf.
Miller HW. Plan and operation of the Health and Nutrition Examination Survey, United States, 1971–1973: Part A, Development, plan, and operation. Vital Health Stat. Hyattsville, MD. NCHS. 1973;1(10a). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_010a.pdf.
NCHS. Plan and operation of the Health and Nutrition Examination Survey, United States, 1971–1973: Part B, Data collection forms of the survey. Vital Health Stat. Hyattsville, MD. NCHS. 1977;1(10b). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_010b.pdf.
Engel A, Murphy RS, Maurer K, Collins E. Plan and operation of the HANES I augmentation survey of adults 25–74 years: United States, 1974–1975. Vital Health Stat. Hyattsville, MD. NCHS. 1978;1(14). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_014.pdf.
McDowell A, Engel A, Massey JT, Maurer K. Plan and operation of the second National Health and Nutrition Examination Survey, 1976–80. Vital Health Stat. Hyattsville, MD. NCHS. 1981;1(15). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_015.pdf.
Maurer KR. Plan and operation of the Hispanic Health and Nutrition Examination Survey, 1982–84. Vital Health Stat. Hyattsville, MD. NCHS. 1985;1(19). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_019.pdf.
Ezzati TM, Massey JT, Waksberg J, Chu A, Maurer KR. Sample design: Third National Health and Nutrition Examination Survey. Vital Health Stat. Hyattsville, MD. NCHS. 1992;2(113). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_113.pdf.
NCHS. Plan and operation of the Third National Health and Nutrition Examination Survey, 1988–94. Vital Health Stat. Hyattsville, MD. NCHS. 1994;1(32). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_032.pdf.

##### For More Information

See the NHANES website at: http://www.cdc.gov/nchs/nhanes.htm.

### National Health Interview Survey (NHIS)

#### CDC/NCHS

##### Overview

NHIS monitors the health of the U.S. population through the collection and analysis of data on a broad range of health topics. A major strength of this survey lies in the ability to analyze health measures by many demographic and socioeconomic characteristics.

##### Selected Content

During household interviews, NHIS obtains information on activity limitation, illnesses, injuries, chronic conditions, health insurance coverage (or lack thereof), utilization of health care, and other health topics. Demographic data reported by respondent or proxy include age, sex, education, race, ethnicity, place of birth, employment status, income, and residence. Other data collected annually include health risk factors such as lack of exercise, smoking, alcohol consumption, and use of prevention services such as vaccinations. Special modules and supplements focus on different issues each year and have covered many topics, including vaccinations; aging; cancer screening, including periodic prevention activities such as mammography, colorectal tests or procedures, and Pap smears; and complementary and alternative medicine.

##### Data Years

NHIS has been conducted annually since 1957, with a major redesign every 10–15 years.

##### Coverage

The survey covers the civilian noninstitutionalized population of the United States. Among those excluded are patients in long-term care facilities, persons on active duty with the Armed Forces (although their dependents are included), incarcerated persons, and U.S. nationals living in foreign countries.

##### Methodology

NHIS is a cross-sectional household interview survey. Sampling and interviewing are continuous throughout each year. The sampling plan follows a multistage area probability design that permits the representative sampling of households. Traditionally, the sample for NHIS is redesigned and redrawn about every 10 years to better measure the changing U.S. population and to meet new survey objectives. A new sample design was implemented in the 2006 survey. The fundamental structure of the new design is very similar to the previous design for the 1995–2005 surveys. Information is presented only for the current sampling plan covering design years 2006–2014. The first stage of the current sampling plan consists of a sample of 428 primary sampling units (PSUs) drawn from approximately 1,900 geographically defined PSUs that cover the 50 states and the District of Columbia. A PSU consists of a county, a small group of contiguous counties, or a metropolitan statistical area.

Within a PSU, two types of second-stage units are used: area segments and permit segments. Area segments are defined geographically and contain an expected 8, 12, or 16 addresses. Permit segments cover housing units built after the 2000 census. The permit segments are defined using updated lists of building permits issued in the PSU since 2000 and contain an expected four addresses. Within each segment, all occupied households at the sample addresses are targeted for interview.

The total NHIS sample of PSUs is subdivided into four separate panels, or subdesigns, such that each panel is a representative sample of the U.S. population. This design feature has a number of advantages, including flexibility for the total sample size. The households selected for interview each week in NHIS are a probability sample representative of the target population.

In the 2006–2014 redesign, the NHIS sample was reduced by 13% compared with the 1995–2005 design. With four sample panels and no sample cuts, the expected NHIS sample size (completed interviews) is approximately 35,000 households containing about 87,500 persons.

Oversampling of the black and Hispanic populations was retained in the 2006–2014 design to allow for more precise estimation of health characteristics in these growing minority populations. The new sample design also oversamples the Asian population. In addition, the sample adult selection process was revised so that when black, Hispanic, or Asian persons 65 years of age and over are present, they have an increased chance of being selected as the sample adult.

The NHIS that was fielded from 1982 through 1996 consisted of two parts: (a) a set of basic health and demographic items (known as the Core questionnaire) and (b) one or more sets of questions on current health topics (known as Supplements). The Core questionnaire remained the same over that time period, whereas the current health topics changed depending on data needs.

The NHIS questionnaire revision, implemented in 1997, has two basic parts: a Basic Module or Core and one or more supplements that vary by year. The Core remains largely unchanged from year to year and allows for trend analysis and for data from more than 1 year to be pooled to increase the sample size for analytic purposes. The Core contains three components: the Family, the Sample Adult, and the Sample Child. The Family component collects information on everyone in the family and allows NHIS to serve as a sampling frame for additional integrated surveys as needed. Information collected in the Family component for all family members includes household composition and sociodemographic characteristics, tracking information, information for matches to administrative databases, health insurance coverage, and basic indicators of health status and utilization of health care services. Information from the Family component is included on the Person file (see the NHIS website, below). From each family in NHIS, one sample adult and, for families with children under 18 years of age, one sample child are randomly selected to participate in the Sample Adult and Sample Child questionnaires. For children, information is provided by a knowledgeable family member 18 years of age or over residing in the household. Because some health issues are different for children and adults, these two questionnaires differ in some items but both collect basic information on health status, use of health care services, health conditions, and health behaviors.

##### Sample Size and Response Rate

Between 1997 and 2005, the sample numbered about 100,000 persons with about 30,000–36,000 persons participating in the Sample Adult and about 12,000–14,000 persons in the Sample Child questionnaires. The NHIS sample was reduced by approximately 50% during the third quarter of 2006, cutting about 13% of the sample size of the original 2006 sample. In 2007, the NHIS sample was reduced by approximately 50% during July–September 2007. The 2007 sample reduction was implemented in the same way and during the same time of year as the 2006 sample reduction. Overall, about 13% of the households in the 2007 NHIS sample were deleted from interviewers’ assignments. The NHIS sample was reduced by approximately 50% during October–December 2008 and by approximately 50% during January–March 2009. The 2009 sample reduction was implemented in the same way as the 2006, 2007, and 2008 sample reductions; however, the timing of the 2009 reduction was different: the 2006 and 2007 reductions occurred during July–September, and the 2008 reduction occurred during October–December. Newly available funding later in 2009 permitted an expansion during October–December to increase that quarter’s normal sample size by approximately 50%. The net effect of the January–March cut and the October–December expansion is that the 2009 NHIS sample size is approximately the same as it would have been if the sample had been maintained at a normal level during the entire calendar year.

In 2010, the NHIS sample was augmented by approximately 25% during January–March. There were no further changes to sample size in the remaining months of 2010. As a result, the 2010 NHIS sample size is slightly larger than the 2009 sample size. In 2010, the sample numbered 89,976 with 27,157 persons participating in the Sample Adult and 11,277 persons in the Sample Child questionnaires. In 2010, the total household response rate was 79%. The final response rate was 61% for the Sample Adult file and 71% for the Sample Child file.

##### Issues Affecting Interpretation

In 1997, the questionnaire was redesigned; some basic concepts were changed, and other concepts were measured in different ways. For some questions there was a change in the reference period. Also in 1997, the collection methodology changed from paper-and-pencil questionnaires to computer-assisted personal interviewing (CAPI). Because of the major redesign of the questionnaire in 1997, most NHIS trend tables in Health, United States begin with 1997 data. Starting with Health, United States, 2005, estimates for 2000–2002 were revised to use 2000-based weights and differ from previous editions of Health, United States that used 1990-based weights for those data years. The weights available on the public-use NHIS files for 2000–2002 are 1990-based. Data for 2003 and later years use weights derived from the 2000 census. In 2006 and beyond, the sample size was reduced, and this is associated with slightly larger variance estimates than in previous years when a larger sample was fielded. Starting in 2010, a geographic nonresponse adjustment was made to both the sample adult weight and the sample child weight. See Moriarity (2009).

##### References

Massey JT, Moore TF, Parsons VL, Tadros W. Design and estimation for the National Health Interview Survey, 1985–94. Vital Health Stat. Hyattsville, MD. NCHS. 1989;2(110). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_110.pdf.
NCHS. National Health Interview Survey: Research for the 1995–2004 redesign. Vital Health Stat. Hyattsville, MD. NCHS. 1999;2(126). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_126.pdf.
Botman SL, Moore TF, Moriarity CL, Parsons VL. Design and estimation for the National Health Interview Survey, 1995–2004. Vital Health Stat. Hyattsville, MD. NCHS. 2000;2(130). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_130.pdf.
Moriarity C. 2009. National Health Interview Survey sample adult and sample child nonresponse bias analysis. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/nhis/nr_bias_analysis_report_2009_NHIS.pdf.

##### For More Information

See the NHIS website at: http://www.cdc.gov/nchs/nhis.htm.

### National Health Interview Survey (NHIS) Linked Mortality File

#### CDC/NCHS

##### Overview

NCHS has conducted a mortality linkage of NHIS with death certificate records from the National Death Index (NDI) to allow researchers to investigate the association of a variety of health factors with mortality, using the richness of the NHIS questionnaires.

##### Selected Content

The restricted-use NHIS Linked Mortality files contain the unique NHIS public-use person ID, mortality status (assumed alive, assumed deceased, ineligible), date of NHIS interview, age at NHIS interview, and adjusted sample weights. For those identified as deceased, the following additional variables are available: age at death, date of death, underlying cause of death codes, and multiple cause of death axis codes. Public-use NHIS Linked Mortality files, with limited variables, are also available.

##### Data Years

NHIS files for 1986–2004 have been linked to mortality data, with mortality ascertained through December 31, 2006. In Health, United States, NHIS years 2000–2004 were pooled with mortality follow-up through December 31, 2006. NHIS years 1990–1994 were combined with mortality follow-up through December 31, 1996.

##### Coverage

NHIS covers the civilian noninstitutionalized population of the United States. The NDI is a centralized database of all deaths occurring in the United States (including New York City, the District of Columbia, the Virgin Islands, and Puerto Rico) beginning in 1979.

##### Methodology

Mortality ascertainment is based primarily on the results from a probabilistic match between NHIS and NDI death certificate records. Seven criteria were used to match NHIS participants to NDI records. For example, records were identified as potential matches if they matched on a combination of social security number; first and last name, exact month of birth, and year of birth within 1 year; or first name, father’s surname, exact month of birth, and exact year of birth. Each potential NDI match then was scored and evaluated according to guidelines developed by NCHS staff to determine if the match was valid.

##### Sample Size and Response Rate

The annual 1990–1994 NHIS sample sizes ranged from 109,000 to 128,000, and response rates were 95% or higher. The annual 2000–2004 NHIS sample sizes ranged from 92,000 to 100,000, and response rates were 87%– 90%. For the 1990–1994 NHIS Linked Mortality files, 2%–3% of NHIS participants were ineligible for mortality follow-up due to insufficient identifying information. For the 2000–2004 NHIS Linked Mortality files, 10%–14% of NHIS participants were ineligible for mortality follow-up due to insufficient information.

##### Issues Affecting Interpretation

For the 1987–2004 Linked Mortality files, adjusted weights based on the original NHIS weights were created for NHIS participants classified as eligible for mortality follow-up. These linkage-eligibility adjusted weights account for those ineligible for linkage to the NDI due to insufficient identifying data. The linkage-eligibility adjusted sample weights provided on the NHIS Linked Mortality files should be used in place of the original NHIS sample weights to reduce potential bias when calculating mortality estimates.

To protect the confidentiality of the NHIS participants, public-use linked mortality files were subjected to data perturbation techniques (which alter some of the data to protect confidentiality), have limited data variables, and only include mortality follow-up for eligible adults, not children. Restricted-use versions of the NHIS Linked Mortality files include children and are available only through the NCHS Research Data Center (RDC).

##### References

NCHS, Office of Analysis and Epidemiology. Comparative analysis of the NHIS public-use and restricted-use Linked Mortality files: 2010 data release. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/NCHS/data/datalinkage/nhis_mort_compare_2010_final.pdf.
NCHS, Office of Analysis and Epidemiology. National Health Interview Survey (1986–2004) Linked Mortality files: Analytic guidelines. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/datalinkage/nhis_mort_analytic_guidelines.pdf.
NCHS, Office of Analysis and Epidemiology. The National Health Interview Survey (1986–2004) Linked Mortality files, mortality follow-up through 2006: Matching methodology. Hyattsville, MD. NCHS. 2009. Available from: http://www.cdc.gov/nchs/data/datalinkage/matching_methodology_nhis_final.pdf.

##### For More Information

See the data linkage website at: http://www.cdc.gov/nchs/data_access/data_linkage/mortality.htm.

### National Hospital Ambulatory Medical Care Survey (NHAMCS)

#### CDC/NCHS

##### Overview

NHAMCS collects data on the utilization and provision of medical care services provided in hospital emergency and outpatient departments.

##### Selected Content

Data are collected from medical records on types of providers seen; reason for visit; diagnoses; drugs ordered, provided, or continued; and selected procedures and tests performed during the visit. Patient data include age, sex, race, and expected source of payment. Data are also collected on selected characteristics of the hospitals included in the survey.

##### Data Years

Annual data collection began in 1992.

##### Coverage

NHAMCS is a representative sample of visits to emergency departments (EDs) and outpatient departments (OPDs) of nonfederal, short-stay, or general hospitals. Telephone contacts are excluded. Starting in 2009, the survey includes a representative sample of visits to hospital-based ambulatory surgery centers (ASCs). Starting in 2010, a representative sample of visits to freestanding ASCs is included.

##### Methodology

A four-stage probability sample design is used in NHAMCS, involving samples of (a) geographically defined primary sampling units (PSUs), (b) hospitals within PSUs, (c) clinics within OPDs, and (d) patient visits within clinics. EDs are treated as their own stratum, and all service areas within EDs are included. The first-stage sample of NHAMCS consists of 112 PSUs selected from 1,900 such units that make up the United States. Within PSUs, 600 general and short-stay hospitals were sampled and assigned to 1 of 16 panels. In any given year, 13 panels are included. Each panel is assigned to a 4-week reporting period during the calendar year.

In the NHAMCS OPD, a clinic is defined as an administrative unit of the OPD in which ambulatory medical care is provided under the supervision of a physician. Clinics where only ancillary services (such as radiology, laboratory services, physical rehabilitation, renal dialysis, and pharmacy) are provided, or other settings in which physician services are not typically provided, are considered out of scope. If a hospital OPD has five or fewer in-scope clinics, all are included in the sample. If an OPD has more than five clinics, the clinics are assigned to one of six specialty groups: general medicine, surgery, pediatrics, obstetrics and gynecology, substance abuse, and other. Within these specialty groups, clinics are grouped into clinic sampling units (SUs). A clinic SU is generally one clinic, except when a clinic expects fewer than 30 visits. In that case, it is grouped with one or more other clinics to form a clinic SU. If the grouped SU is selected, all clinics included in that SU are included in the sample. Prior to 2001, a sample of generally five clinic SUs was selected per hospital, based on probability proportional to the total expected number of patient visits to the clinic during the assigned 4-week reporting period. Starting in 2001, clinic sampling within each hospital was stratified. If an OPD had more than five clinics, two clinic SUs were selected from each of the six specialty groups with a probability proportional to the total expected number of visits to the clinic. The change was made to ensure that at least two SUs were sampled from each of the specialty group strata.

The U.S. Census Bureau acts as the data collection agent for NHAMCS. Census field representatives contact sample hospitals to determine whether they have a 24-hour ED or an OPD that offers physician services. Visits to eligible EDs and OPDs are systematically sampled over the 4-week reporting period such that about 100 ED encounters and about 200 OPD encounters are selected. Hospital staff are asked to complete patient record forms (PRFs) for each sampled visit, but census field representatives typically abstract data for more than one-third of these visits.

Sample data are weighted to produce national estimates. The estimation procedure used in NHAMCS has three basic components: inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and ratio adjustment to fixed totals.

##### Sample Size and Response Rate

In any given year, the hospital sample consists of approximately 500 hospitals, of which 80% have EDs and about one-half have eligible OPDs. Typically, about 1,000 clinics are selected from participating hospital OPDs.

In each sample year from 2002 through 2008, the number of PRFs completed for EDs ranged from 33,000 to 40,000 and for OPDs from 30,000 to 36,000. The hospital response rate was 83%–94% for EDs and 73%–84% for OPDs during this timeframe. In 2008, the number of PRFs completed for EDs was 34,134 and for OPDs was 33,908, and the hospital response rate was 87% for EDs and 75% for OPDs. In 2009, the number of PRFs completed for EDs was 34,942 and for OPDs was 33,551, and the hospital response rate was 83% for EDs and 73% for OPDs.

##### Issues Affecting Interpretation

The NHAMCS PRF is modified approximately every 2 to 4 years to reflect changes in physician practice characteristics, patterns of care, and technological innovations. Examples of recent changes include an increase in the number of drugs recorded on the PRF form and adding checkboxes for specific tests or procedures performed.

##### Reference

McCaig LF, McLemore T. Plan and operation of the National Hospital Ambulatory Medical Care Survey. Vital Health Stat. Hyattsville, MD. NCHS. 1994;1(34). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_034acc.pdf.

##### For More Information

See the National Health Care Surveys website at: http://www.cdc.gov/nchs/dhcs.htm and the Ambulatory Health Care Data website at: http://www.cdc.gov/nchs/ahcd.htm.

### National Hospital Discharge Survey (NHDS)

#### CDC/NCHS

##### Overview

NHDS collects and produces national estimates on characteristics of inpatient stays in nonfederal, short-stay hospitals in the United States.

##### Selected Content

Patient information collected includes demographics, length of stay, diagnoses, and procedures. Hospital characteristics collected include region, ownership, and bed size.

##### Data Years

NHDS has been conducted annually since 1965.

##### Coverage

The survey design covers the 50 states and the District of Columbia. Included in the survey are hospitals with an average length of stay of less than 30 days for all inpatients, general hospitals, and children’s general hospitals. Excluded are federal, military, and Department of Veterans Affairs hospitals, as well as hospital units of institutions (such as prison hospitals) and hospitals with fewer than six beds staffed for patient use. All discharged patients from in-scope hospitals are included in the survey; however, data for newborns are not included in Health, United States.

##### Methodology

The NHDS design implemented in 1965 continued through 1987, and a redesign with a new sample of hospitals, fielded in 1988, was in place up until 2010 when the survey was redesigned. The sample for the 1965 NHDS was selected in 1964 from a frame of short-stay hospitals listed in the National Master Facility Inventory. A two-stage stratified sample design was used, with hospitals stratified according to bed size and geographic region. Sample hospitals were selected with probabilities ranging from certainty for some hospitals to 1 in 40 for other hospitals. Within each participating hospital, a systematic random sample was selected from a daily listing sheet of discharges. Within-hospital sampling rates for discharges varied inversely with the probability of hospital selection, so the overall probability of selecting a discharge was approximately the same across the sample.

Data collection was conducted by manual abstraction of patient information from sampled medical records. Sample selection and transcription of information from inpatient medical records to NHDS survey forms were performed by hospital staff, representatives of NCHS, or both. In 1985, a second data collection procedure was introduced that involved the purchase of computer data tapes from commercial abstracting services that contained automated discharge data for some hospitals participating in NHDS. This procedure was used in approximately 17% of the sample hospitals for 1985–1987. Discharges on these computer files were subjected to the NHDS sampling specifications as well as the computer edits and estimation procedures. Both data collection methods, manual and automated, continue to be used in NHDS.

A redesign of NHDS was implemented for the 1988 survey. Under the redesign, hospitals were selected using a modified three-stage stratified design. Units selected at the first stage consisted of either hospitals or geographic areas. The geographic areas were the primary sampling units (PSUs) used for the 1985–1994 National Health Interview Survey, which are geographic areas such as counties or townships. Hospitals within PSUs were then selected at the second stage. Strata at this stage were defined by geographic region, PSU size, abstracting service status, and hospital specialty-size groups. Within these strata, hospitals were selected with probabilities proportional to their annual number of discharges. At the third stage, a sample of discharges was selected by a systematic random sampling technique. The sampling rate was determined by the hospital’s sampling stratum and the type of data collection system (manual or automated) used. Discharge records from hospitals submitting data from commercial abstracting services and selected state data systems (close to one-half of sample hospitals in 2008–2009) were arrayed by primary diagnoses, patient sex and age group, and date of discharge, before sampling.

The NHDS hospital sample has generally been updated every 3 years by continuing the sampling process among hospitals that become eligible for the survey during the intervening years and by deleting hospitals that are no longer eligible. This update was conducted in 1991, 1994, 1997, 2000, 2003, and 2006.

The basic unit of estimation for NHDS is a sampled discharge. The basic estimation procedure involves inflation by the reciprocal of the probability of selection. Adjustments are made for nonresponding hospitals and discharges, and a post-ratio adjustment to fixed totals is employed.

##### Sample Size and Response Rate

Due to funding limitations, the 2008 and 2009 survey sample sizes were cut in half. In 2008, 239 hospitals were selected: 238 were within scope, 207 participated (87%), and data were collected from medical records for approximately 165,000 discharges. In 2009, 239 hospitals were selected: 238 were within scope, 205 participated (86%), and data were collected from medical records for approximately 162,000 discharges.

##### Issues Affecting Interpretation

NHDS was redesigned in 1988, and the sample size was cut in half for the 2008 and 2009 surveys, therefore caution is required in comparing trend data from before and after these changes. In particular, the smaller sample size for the 2008 and 2009 surveys has resulted in larger standard error estimates for statistics produced by the survey, and in some cases the relative standard errors have doubled. Special care should be taken when making estimates for children under 15 years of age and for the West Census region because a review of a variety of estimates for these populations showed that many do not meet NCHS standards of reliability. In addition, annual modifications to the International Classification of Diseases, 9th Revision, Clinical Modification (ICD–9–CM) may affect diagnosis and procedure categories. [See Appendix II, International Classification of Diseases, 9th Revision, Clinical Modification (ICD–9–CM); Table X; Table XI]

Hospital utilization rates per 10,000 population were computed using estimates of the civilian population of the United States as of July 1 of each year. Rates for 1990–1999 use postcensal estimates of the civilian population based on the 1990 census, adjusted for net underenumeration using the 1990 National Population Adjustment Matrix from the U.S. Census Bureau. The estimates for 2000 and beyond that appear in Health, United States, 2003 and later editions were calculated using estimates of the civilian population based on the 2000 census, and therefore are not strictly comparable with postcensal rates calculated for the 1990s. (See Appendix I, Population Census and Population Estimates.)

##### References

Hall MJ, DeFrances CJ, Williams SN, Golosinskiy A, Schwartzman A. National Hospital Discharge Survey: 2007 summary. National health statistics reports. Hyattsville, MD. NCHS. 2010;(29). Available from: http://www.cdc.gov/nchs/data/nhsr/nhsr029.pdf.
Dennison C, Pokras R. Design and operation of the National Hospital Discharge Survey: 1988 Redesign. Vital Health Stat. Hyattsville, MD. NCHS. 2000;1(39). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_039.pdf.
Haupt BJ, Kozak LJ. Estimates from two survey designs: National Hospital Discharge Survey. Vital Health Stat. Hyattsville, MD. NCHS. 1992;13(111). Available from: http://www.cdc.gov/nchs/data/series/sr_13/sr13_111.pdf.

##### For More Information

See the National Health Care Surveys website at: http://www.cdc.gov/nchs/dhcs.htm and the National Hospital Discharge Survey website at: http://www.cdc.gov/nchs/nhds.htm.

### National Immunization Survey (NIS)

#### CDC/National Center for Immunization and Respiratory Diseases (NCIRD) and NCHS

##### Overview

NIS is a continuing nationwide telephone sample survey to monitor vaccination coverage rates among children 19–35 months of age and among teenagers (NIS–Teen) 13–17 years of age.

##### Selected Content

Data collected for children include vaccination status and date of vaccinations for diphtheria, tetanus toxoids, and acellular pertussis vaccine (DTP/DT/DTaP); poliovirus vaccine (Polio); measles, mumps, and rubella vaccine (MMR); Haemophilus influenzae type b vaccine (Hib); hepatitis B vaccine (Hep B); varicella zoster vaccine; pneumococcal conjugate vaccine (PCV); hepatitis A (Hep A); influenza; and for adolescents, meningococcal conjugate vaccine (MCV4) and human papillomavirus vaccine (HPV). Demographic data include age, gender, race and ethnicity, and poverty level. Data are available at a variety of geographic levels, including census regions, states, and selected urban areas.

##### Data Years

Annual household data collection was initiated beginning with data year 1994. Data collection for varicella began in July 1996; data collection for PCV began in July 2001. Data collection for adolescents 13–17 years of age began in 2006.

##### Coverage

Children 19–35 months of age and adolescents 13–17 years of age in the civilian noninstitutionalized population are represented in this survey. Estimates of vaccine-specific coverage are available for the Nation, states, and selected urban areas.

##### Methodology

NIS is a nationwide telephone sample survey of households with age-eligible children. The survey uses a two-phase sample design. First, a random-digit-dialing sample of telephone numbers is drawn. When households with age-eligible children are contacted, the interviewer collects information on the vaccinations received by all age-eligible children and obtains permission to contact the children’s vaccination providers. Second, identified providers are sent vaccination history questionnaires by mail. Providers’ responses are compared with information obtained from households to provide a more accurate estimate of vaccination coverage levels. Final estimates are adjusted for households without telephones and for nonresponse. NIS–Teen followed the same sample design and data collection procedures as NIS except that only one age-eligible adolescent was selected from each household for data collection.

##### Sample Size and Response Rate

In 2009, vaccination data were collected from providers for 17,313 children 19–35 months of age. The overall interview response rate was 64%. Vaccination information from providers was obtained for 71% of all children who were eligible for provider follow-up in 2009.

Also in 2009, vaccination data were collected from providers for 20,399 adolescents 13–17 years of age. The overall interview response rate was 58%. Vaccination information from providers was obtained for 57% of all adolescents who were eligible for provider follow-up in 2009.

##### Issues Affecting Interpretation

For data years 1998, 2002, 2004, and 2005, slight modifications to the estimation procedure were implemented to obtain vaccination coverage rates from the provider data. Published estimates of vaccination coverage based on NIS data for years prior to 1998 [e.g., estimates published in Morbidity and Mortality Weekly Report (MMWR) articles] may differ slightly from estimates published in Health, United States and on the NIS website for the same data. All released public-use data files include the sampling weights using the revised estimation procedure. The findings in recent years are subject to at least three limitations. First, NIS is a telephone survey, and statistical adjustments might not compensate fully for nonresponse and for households without landline telephones. Second, underestimates of vaccination coverage might have resulted in exclusive use of provider-reported vaccination histories because completeness of records is unknown. Finally, although national coverage estimates are precise, annual estimates and trends for state and local areas should be interpreted with caution because of smaller sample sizes and wider confidence intervals.

Before January 2009, NIS did not distinguish between Hib vaccine production types; therefore, children who received three doses of a vaccine product that requires four doses were misclassified as fully vaccinated. For more information, see “Changes in Measurement of Haemophilus influenzae serotype b (Hib) Vaccination Coverage—National Immunization Survey, United States, 2009” (2010).

##### References

CDC. National, state, and local area vaccination coverage among children aged 19–35 months—United States, 2009. MMWR. 2010;59(36):1171-7. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5936a2.htm?s_cid=mm5936a2_w.
CDC. National, state, and local area vaccination coverage among adolescents aged 13–17 years—United States, 2009. MMWR. 2010;59(32):1018-23. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5932a3.htm?s_cid=mm5932a3_w.
Smith PJ, Hoaglin DC, Battaglia MP, et al. Statistical methodology of the National Immunization Survey, 1994–2002. Vital Health Stat. Hyattsville, MD. NCHS. 2005;2(138). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_138.pdf.
CDC. Changes in measurement of Haemophilus influenzae serotype b (Hib) vaccination coverage— National Immunization Survey, United States, 2009. MMWR. 2010;59(33):1069-72. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5933a3.htm?s_cid=mm5933a3_e%0d%0a.

##### For More Information

See the NIS website at: http://www.cdc.gov/nchs/nis.htm.

### National Income and Product Accounts (NIPA)

#### Bureau of Economic Analysis (BEA)

##### Overview

NIPA are a set of economic accounts that provide detailed measures of the value and composition of national output and the incomes generated in the production of that output. Essentially, NIPA provide a detailed snapshot of the myriad transactions that make up the economy— buying and selling goods and services, hiring of labor, investing, renting property, paying taxes, and the like. NIPA estimates show U.S. production, distribution, consumption, investment, and saving.

##### Selected Content

The best-known NIPA measure is the Gross Domestic Product (GDP), which is defined as the market value of the goods and services produced by labor and property located in the United States. NIPA calculate GDP as the sum of familiar final expenditure components: personal consumption expenditures, private investment, government spending (consumption and investment), and net exports. However, GDP is just one of many economic measures presented in NIPA. Other key NIPA estimates presented in Health, United States include the implicit price deflator for GDP and federal and state and local government expenditures.

The conceptual framework of NIPA is illustrated by seven summary accounts: the domestic income and product account, the private enterprise income account, the personal income and outlay account, the government receipts and expenditures account, the foreign transactions current account, the domestic capital account, and the foreign transactions capital account. These summary accounts record a use (or expenditure) in one account for one sector and a corresponding source (or receipt) in an account of another sector or of the same sector. This integrated system provides a comprehensive measure of economic activity in a consistently defined framework without double counting.

##### Data Years

Estimates of national income were developed in response to the lack of comprehensive economic data during the Great Depression. Initial estimates were presented in a 1934 report to the U.S. Senate, National Income, 1929–32. The U.S. national income and product statistics were first presented as part of a complete and consistent double-entry accounting system in the summer of 1947.

##### Coverage

Source data for NIPA domestic estimates cover all 50 states and the District of Columbia.

##### Methodology

NIPA estimates are revised on a quarterly, annual, and quinquennial basis. For GDP and most other NIPA series, a set of three current quarterly estimates are released each year. Quarterly estimates provide the first look at the path of U.S. economic activity. Annual revisions of NIPA are usually carried out each summer. These revisions incorporate source data that are based on more extensive annual surveys, on annual data from other sources, and on later revisions to the monthly and quarterly source data, and they generally cover the three previous calendar years. Comprehensive revisions are carried out at about 5-year intervals and may result in revisions that extend back for many years. These estimates incorporate all of the best available source data, such as data from the quinquennial U.S. Economic Census.

NIPA measures are built up from a wide range of source data using a variety of estimating methods. To ensure consistency and accuracy, NIPA use various adjustment and estimation techniques to estimate data. Three general types of adjustments are made to the source data that are incorporated into the NIPA estimates. The first consists of adjustments that are needed so that the data conform to appropriate NIPA concepts and definitions. The second type of adjustment involves filling gaps in coverage. The third type of adjustment involves time of recording and valuation. Source data must occasionally be adjusted to account for special circumstances that affect the accuracy of the data. For example, quarterly and monthly NIPA estimates are seasonally adjusted at the detailed-series level when the series demonstrate statistically significant seasonal patterns. Source data may also be used as indicators to extrapolate annual estimates. For more information, see “An Introduction to the National Income and Product Accounts Methodology Papers: U.S. National Income and Product Accounts,” available from: http://www.bea.gov/scb/pdf/national/nipa/methpap/mpi1_0907.pdf and “Concepts and Methods of the U.S. National Income and Product Accounts,” available from: http://www.bea.gov/national/pdf/chapters1-4.pdf.

##### Issues Affecting Interpretation

NIPA estimates are released on a quarterly, annual, and quinquennial basis because the source data are frequently revised. Data are released at different times and estimates are updated as they become available, new concepts or definitions are incorporated, and source data may change due to improvements in collection and new methodologies. As a result, major estimates such as GDP and its major components undergo frequent revision and historical data are changed. For more information, see the BEA (NIPA) website at: http://www.bea.gov/national/an1.htm#2011AnnualRevision.

##### Reference

U.S. Bureau of Economic Analysis (BEA). A guide to the National Income and Product Accounts of the United States. Washington, DC. BEA. 2006. Available from: http://www.bea.gov/national/pdf/nipaguid.pdf.

##### For More Information

See the BEA (NIPA) website at: http://www.bea.gov/national/index.htm.

### National Medical Expenditure Survey (NMES)—See Medical Expenditure Panel Survey

### National Notifiable Disease Surveillance System (NNDSS)

#### CDC

##### Overview

NNDSS provides weekly provisional information on the occurrence of diseases defined as notifiable by the Council of State and Territorial Epidemiologists (CSTE).

##### Selected Content

Data include incidence of reportable diseases using uniform case definitions.

##### Data Years

The first annual summary of the notifiable diseases in 1912 included reports of 10 diseases from 19 states, the District of Columbia (D.C.), and Hawaii. By 1928, all states, D.C., Hawaii, and Puerto Rico were participating in national reporting of 29 specified diseases. At their annual meeting in 1950, state and territorial health officers authorized a conference of state and territorial epidemiologists whose purpose was to determine which diseases should be reported to Public Health Service. In 1961, CDC assumed responsibility for the collection and publication of data concerning nationally notifiable diseases.

##### Coverage

Notifiable disease reports are received from health departments in the 50 states, five territories, D.C., and New York City. Policies for reporting notifiable disease cases can vary by disease or reporting jurisdiction, depending on case status classification (i.e., confirmed, probable, or suspect).

##### Methodology

CDC, in partnership with CSTE, operates NNDSS. Notifiable disease surveillance is conducted by public health practitioners at local, state, and national levels to support disease prevention and control. The system also provides annual summaries of the data. CSTE and CDC annually review the status of national infectious disease surveillance and recommend additions or deletions to the list of nationally notifiable diseases, based on the need to respond to emerging priorities. For example, Q fever and tularemia became nationally notifiable in 2000. However, reporting nationally notifiable diseases to CDC is voluntary. Because reporting is currently mandated by law or regulation only at the local and state levels, the list of diseases that are considered notifiable varies slightly by state. For example, reporting of cyclosporiasis to CDC is not done by some states in which this disease is not notifiable to local or state authorities.

State epidemiologists report cases of notifiable diseases to CDC, which tabulates and publishes these data in Morbidity and Mortality Weekly Report (MMWR) and in Summary of Notifiable Diseases, United States (before 1985, titled Annual Summary).

##### Issues Affecting Interpretation

NNDSS data must be interpreted in light of reporting practices. Some diseases that cause severe clinical illness (for example, plague and rabies) are likely reported accurately if diagnosed by a clinician. However, persons who have diseases that are clinically mild and infrequently associated with serious consequences (e.g., salmonellosis) may not seek medical care from a health care provider. Even if these less severe diseases are diagnosed, they are less likely to be reported.

The degree of completeness of data reporting is also influenced by the diagnostic facilities available, the control measures in effect, public awareness of a specific disease, and the interests, resources, and priorities of state and local officials responsible for disease control and public health surveillance. Finally, factors such as changes in case definitions for public health surveillance, introduction of new diagnostic tests, or discovery of new disease entities can cause changes in disease reporting that are independent of the true incidence of disease.

##### Reference

CDC. Summary of notifiable diseases—United States, 2008. MMWR. 2010;57(54):1-94. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5754a1.htm.

##### For More Information

See the NNDSS website at: http://www.cdc.gov/osels/ph_surveillance/nndss/nndsshis.htm.

### National Survey of Children’s Health (NSCH)

#### CDC/NCHS and Health Resources and Services Administration

##### Overview

NSCH, a module of the State and Local Area Integrated Telephone Survey (SLAITS), produces national and state-specific prevalence estimates for a variety of physical, emotional, and behavioral health indicators for children.

##### Selected Content

NSCH obtains information on chronic conditions, activity limitation, health insurance coverage, and other health topics. Special emphasis is placed on factors that may relate to well-being of children, including medical homes, family interactions, parental health, school and after-school experiences, and safe neighborhoods. Demographic data gathered include age, sex, and residence. Other data collected include use of medical care, mental health, and educational services, and behavioral data, such as daily exercise, sleep, and computer and television time.

##### Data Years

NSCH was first conducted in 2003 and was repeated in 2007. Data collection for the 2011 survey was recently completed.

##### Coverage

Children under 18 years of age in the civilian noninstitutionalized population are represented in this survey.

##### Methodology

NSCH uses the sampling frame of the National Immunization Survey (NIS) and immediately follows NIS in selected households, using its sampling for efficiency and economy. A random-digit-dialed sample of households with children under 18 years of age was selected from the NIS sample frame in each of the 50 states and the District of Columbia. The basic design objective of the NSCH sample was to interview a sample of 1,700 children younger than 18 years of age in each state and the District of Columbia. The sample was selected by identifying households with children under 18. If only one child lived in the household, that child was the target of the interview. If more than one child was present, one child was randomly selected as the target. The respondent was a parent or guardian who knew about the child’s health and health care.

##### Sample Size and Response Rate

For the 2007 NSCH, a total of 91,642 interviews were completed. The weighted overall response rate was 46.7%. For the 2003 NSCH, a total of 102,353 interviews were completed, and the weighted overall response rate was 55.3%.

##### Issues Affecting Interpretation

NSCH is a telephone survey, and statistical adjustments might not compensate fully for nonresponse and for households without landline telephones.

##### References

Blumberg SJ, Foster EB, Frasier AM, et al. Design and Operation of the National Survey of Children’s Health, 2007. Vital Health Stat. Hyattsville, MD. NCHS. 2012;1(55). (Draft available from: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/slaits/nsch07/2_Methodology_Report/NSCH_Design_and_Operations_052109.pdf.).
Blumberg SJ, Olson L, Frankel MR, et al. Design and operation of the National Survey of Children’s Health, 2003. Vital Health Stat. Hyattsville, MD. NCHS. 2005;1(43). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_043.pdf.

##### For More Information

See the National Survey of Children’s Health website at: http://www.cdc.gov/nchs/slaits/nsch.htm.

### National Survey on Drug Use & Health (NSDUH)

#### Substance Abuse and Mental Health Services Administration (SAMHSA)

##### Overview

NSDUH, formerly called the National Household Survey on Drug Abuse (NHSDA), collects data on substance use, abuse, and dependence; mental health problems; and receipt of substance abuse and mental health treatment.

##### Selected Content

NSDUH reports on the prevalence, incidence, and patterns of drug and alcohol use and abuse in the general U.S. civilian noninstitutionalized population 12 years of age and over. Data are collected on the use of the following substances: illicit drugs, including marijuana or hashish, cocaine (including crack), inhalants, hallucinogens, heroin, or nonmedical use of prescription-type psychotherapeutics (including stimulants, sedatives, tranquilizers, and pain relievers); alcohol; and tobacco. NSDUH also reports on substance use disorders, substance use treatment, health care, mental health disorders, and mental health service utilization.

##### Data Years

In 2002, the survey was redesigned, its name was changed to NSDUH, and a monetary incentive for participation was introduced. NSDUH replaces NHSDA, which had been conducted periodically since 1971 and annually starting in 1990.

##### Coverage

The survey is representative of persons 12 years of age and over in the civilian noninstitutionalized population of the United States, and representative in each state and the District of Columbia. NSDUH oversamples youths and young adults.

The survey covers residents of households (including those living in houses, townhouses, apartments, and condominiums), persons in noninstitutional group quarters (including those in shelters, boarding houses, college dormitories, migratory work camps, and halfway houses), and civilians living on military bases. Persons excluded from the survey include homeless people who do not use shelters, active military personnel, and residents of institutional group quarters such as jails and hospitals.

##### Methodology

The data collection method is in-person interviews conducted with a sample of individuals at their place of residence. Computer-assisted interviewing (CAI) methods, including audio computer-assisted self-interviewing (ACASI), are used to provide a private and confidential setting to complete the interview.

NSDUH uses a 50-state sample design. In 2005, NSDUH introduced a coordinated 5-year sample design in which the first stage of selection involved census tracts, with sample segments within a single census tract to the extent possible. States were first stratified into a total of 900 state sampling (SS) regions (48 regions in each large sample state and 12 regions in each small sample state). These regions were contiguous geographic areas designed to yield the same number of interviews on average. Starting with the 2005 survey, a total of 48 census tracts per SS region were selected with probability proportional to size. Within sampled census tracts, adjacent census blocks were combined to form the second-stage sampling units, or area segments. Of these segments, 24 were designated for the coordinated 5-year sample and 24 were designated as reserve segments. Eight sample segments per SS region were fielded during the survey year. These sampled segments were allocated equally into four separate samples, one for each 3-month period (calendar quarter) during the year, so that the survey was essentially continuous in the field.

The design also oversampled youths and young adults, so that each state’s sample was approximately equally distributed among three major age groups: 12–17 years, 18–25 years, and 26 years and over.

##### Sample Size and Response Rate

Nationally, 143,565 household addresses were successfully screened for the 2009 survey, conducted from January to December 2009. In these screened households, a total of 85,429 sample persons were selected, from which 68,700 completed interviews were obtained. Weighted response rates were 89% for household screening and 76% for interviewing.

##### Issues Affecting Interpretation

Several improvements to the survey were implemented in 2002, when the survey was redesigned as NSDUH. In addition to the name change, respondents were offered a $30 incentive payment for participation in the survey starting in 2002, and quality control procedures for data collection were enhanced in 2001 and 2002. Because of these improvements and modifications, estimates from NSDUH completed in 2002 and later should not be compared with estimates from the 2001 or earlier versions of the survey. The data collected in 2002 represent a new baseline for tracking trends in substance use and other measures. Special questions on methamphetamine were added in 2005 and 2006. Data for years prior to 2007 were adjusted for comparability. Estimates of substance use for youth based on NSDUH are not directly comparable with estimates based on the Monitoring the Future (MTF) Study and the Youth Risk Behavior Survey (YRBS). In addition to the fact that MTF excludes dropouts and absentees, rates are not directly comparable across these surveys because of differences in the populations covered, sample design, questionnaires, and interview setting. NSDUH collects data in residences, whereas MTF and YRBS collect data in school classrooms. Further, NSDUH estimates are tabulated by age, whereas MTF and YRBS estimates are tabulated by grade, representing different ages as well as different populations.

##### References

Substance Abuse and Mental Health Services Administration (SAMHSA). State estimates of substance use from the 2007–2008 National Surveys on Drug Use and Health. NSDUH series H–37; HHS pub no SMA 10–4472. Rockville, MD. SAMHSA, Office of Applied Studies. 2010. Available from: http://www.oas.samhsa.gov/2k8State/toc.cfm.
Substance Abuse and Mental Health Services Administration (SAMHSA). Results from the 2009 National Survey on Drug Use and Health. Summary of national findings. NSDUH series H–38A; HHS pub no SMA 10–4586. Rockville, MD. SAMHSA, Office of Applied Studies. 2010;I. Available from: http://oas.samhsa.gov/NSDUH/2k9NSDUH/2k9Results.htm.

##### For More Information

See the NSDUH website at: http://oas.samhsa.gov/nsduh.htm and the Center for Behavioral Health Statistics and Quality (the data collection agency) website at: http://www.samhsa.gov/about/cbhsq.aspx.

### National Survey of Family Growth (NSFG)

#### CDC/NCHS

##### Overview

NSFG provides national data on factors affecting birth and pregnancy rates, adoption, and maternal and infant health.

##### Selected Content

Data elements include sexual activity, marriage, divorce and remarriage, unmarried cohabitation, forced sexual intercourse, contraception and sterilization, infertility, breastfeeding, pregnancy loss, low birthweight, and use of medical care for family planning and infertility.

##### Data Years

Several cycles of the survey have been completed: 1973, 1976, 1982, 1988, 1995, 2002, and 2006–2008. In 2011, NSFG released a 2006–2010 cycle that included the 2006–2008 data.

##### Coverage

The 1973–1995 cycles of NSFG were based on samples of women 15–44 years of age in the civilian noninstitutionalized population of the United States. Cycles 1 and 2 (1973 and 1976) excluded most women who had never been married. Cycles 3–5 (1982, 1988, and 1995) included all women 15–44 years of age in the civilian noninstitutionalized population of the United States. Cycles 6 (2002) and 7 (2006–2010) included men and women 15–44 years of age in the household population of the United States.

##### Methodology

Interviews are conducted in person by professional female interviewers using a standardized questionnaire. In all cycles, black women were sampled at higher rates than white women so that detailed statistics for black women could be produced. In cycles 5 and 6 (1995 and 2002), Hispanic persons were also oversampled. In cycle 7 (2006–2010), black and Hispanic adults and all 15–19 year olds were oversampled.

To produce national estimates from the sample for the millions of women 15–44 years of age in the United States, data for the interviewed sample women were (a) inflated by the reciprocal of the probability of selection at each stage of sampling (for example, if there was a 1 in 5,000 chance that a woman would be selected for the sample, her sampling weight was 5,000); (b) adjusted for nonresponse; and (c) poststratified, or forced to agree with benchmark population values based on data from the U.S. Census Bureau.

##### Sample Size and Response Rate

For cycle 1, from 101 primary sampling units (PSUs), 10,879 women 15–44 years of age were selected; 9,797 of these were interviewed. In cycle 2, from 79 PSUs, 10,202 eligible women were identified; of these, 8,611 were interviewed. In cycle 3, household screener interviews were completed in 29,511 households (95%). Of the 9,964 eligible women identified, 7,969 were interviewed. In cycle 4, 10,566 eligible women 15–44 years of age were sampled, and interviews were completed with 8,450 women. The response rate for the 1990 telephone re-interview was 68% of those responding to the 1988 survey and still eligible for the 1990 survey. In cycle 5, of the 13,795 eligible women in the sample, 10,847 were interviewed. In cycle 6, from 120 PSUs, 7,643 (about 80%) interviews were completed with eligible women and 4,928 (78%) interviews were completed with men. In the 2006–2008, from 110 PSUs, 7,356 (76%) interviews were completed with eligible women and 6,139 (73%) interviews were completed with men. In the 2006–2010 cycle, from 110 PSUs, 12,279 (78%) interviews were completed with eligible women and 10,403 (75%) interviews were completed with men.

##### References

French DK. National Survey of Family Growth, Cycle I: Sample design, estimation procedures, and variance estimation. Vital Health Stat. Hyattsville, MD. NCHS. 1978;2(76). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_076.pdf.
Grady WR. National Survey of Family Growth, Cycle II: Sample design, estimation procedures, and variance estimation. Vital Health Stat. Hyattsville, MD. NCHS. 1981;2(87). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_087.pdf.
Bachrach CA, Horn MC, Mosher WD, Shimizu I. National Survey of Family Growth, Cycle III: Sample design, weighting, and variance estimation. Vital Health Stat. Hyattsville, MD. NCHS. 1985;2(98). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_098.pdf.
Judkins DR, Mosher WD, Botman S. National Survey of Family Growth: Design, estimation, and inference. Vital Health Stat. Hyattsville, MD. NCHS. 1991;2(109). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_109.pdf.
Göksel H, Judkins DR, Mosher WD. Nonresponse adjustments for a telephone follow-up to a national in-person survey. J Off Stat. 1992;8(4):417-31.
Kelly JE, Mosher WD, Duffer AP, Kinsey SH. Plan and operation of the 1995 National Survey of Family Growth. Vital Health Stat. Hyattsville, MD. NCHS. 1997;1(36). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_036.pdf.
Potter FJ, Iannacchione VG, Mosher WD, et al. Sample design, sampling weights, imputation, and variance estimation in the 1995 National Survey of Family Growth. Vital Health Stat. Hyattsville, MD. NCHS. 1998;2(124). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_124.pdf.
Groves RM, Benson G, Mosher WD, et al. Plan and operation of cycle 6 of the National Survey of Family Growth. Vital Health Stat. Hyattsville, MD. NCHS. 2005;1(42). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_042.pdf.
Lepkowski JM, Mosher WD, Davis KE, et al. The 2006–2010 National Survey of Family Growth: Sample design and analysis of a continuous survey. Vital Health Stat. Hyattsville, MD. NCHS. 2010;2(150). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_150.pdf.

##### For More Information

See the NSFG website at: http://www.cdc.gov/nchs/nsfg.htm.

### National Survey of Mental Health Treatment Facilities (NSMHTF)

#### Substance Abuse and Mental Health Services Administration (SAMHSA)

##### Overview

NSMHTF expanded the scope of the Inventory/Survey of Mental Health Organizations (IMHO/SMHO) to address the need to move from an organization-based survey to a point-of-contact or facility-based survey of the known universe of specialty mental health organizations in the United States and to become more aligned with SAMHSA’s National Survey of Substance Abuse Treatment Services (N–SSATS). NSMHTF is expected to continue biennially on the entire inventory of eligible mental health organizations and point-of-contact facilities.

##### Selected Content

NSMHTF collected basic information on the number and characteristics of specialty mental health facilities in the United States, such as type of mental health facility, ownership, types of treatment services offered, sources of payment and funding for services, number of residents and persons in treatment, and number of beds.

##### Data Years

The national mental health service survey known as IMHO/SMHO was redesigned and renamed the National Survey of Mental Health Treatment Facilities (NSMHTF) prior to its initial fielding in 2008.

##### Coverage

Organizations included state psychiatric hospitals, private psychiatric hospitals, nonfederal general hospitals with separate psychiatric services, Department of Veterans Affairs medical centers, residential treatment centers for children with emotional disturbance, and other mental health organizations including freestanding psychiatric outpatient clinics, freestanding partial care organizations, residential treatment centers for adults, and multiservice (multisetting) mental health organizations not elsewhere classified.

##### Methodology

A single-version questionnaire was mailed to the known universe of mental health facilities in the United States. Facilities were given the option for Web-based questionnaire completion; computer-assisted telephone interviewing (CATI) was used as follow-up. The questionnaire included data items about facility-level characteristics and client counts by type of service setting offered at the facility—inpatient, residential, and outpatient (i.e., less than 24-hour care).

##### Sample Size and Response Rate

NSMHTF included approximately 15,000 point-of-contact facilities in the United States representing approximately 4,400 mental health organizations. It had an overall survey response rate of 74%.

##### Issues Affecting Interpretation

In addition to issues addressed in the IMHO/SMHO entry, it is important to note that the 2008 NSMHTF collected data at the point-of-contact facility level. The data were summarized to produce organization-level statistics that can be used when making comparisons with data collected in previous years through IMHO.

##### Reference

Unpublished data are available from SAMHSA’s Center for Behavioral Health Statistics and Quality.

##### For More Information

See the SAMHSA website: http://samhsa.gov.

### National Vital Statistics System (NVSS)

#### CDC/NCHS

##### Overview

NVSS collects and publishes official national statistics on births, deaths, fetal deaths, and, prior to 1996, marriages and divorces occurring in the United States, based on U.S. Standard Certificates. Fetal deaths are classified and tabulated separately from other deaths. The vital statistics files—Birth, Fetal Death, Mortality, Multiple Cause-of-Death, Linked Birth/Infant Death, and Compressed Mortality—are described in detail below.

##### Data Years

The death registration area for 1900 consisted of 10 states, the District of Columbia (D.C.), and a number of cities located in nonregistration states; it covered 40% of the continental U.S. population. The birth registration area was established in 1915 with 10 states and D.C. The birth and death registration areas continued to expand until 1933, when they included all 48 states and D.C. Alaska and Hawaii were added to both registration areas in 1959 and 1960, respectively—the years in which they gained statehood.

##### Coverage

NVSS collects and presents U.S. resident data for the aggregate of 50 states, New York City, and D.C., as well as for each individual state and D.C. Vital events occurring in the United States to non-U.S. residents, and vital events occurring abroad to U.S. residents, are excluded.

##### Methodology

NCHS’ Division of Vital Statistics obtains information on births and deaths from the registration offices of each of the 50 states, New York City, D.C., Puerto Rico, the U.S. Virgin Islands, Guam, American Samoa, and Northern Mariana Islands. Until 1972, microfilm copies of all death certificates and a 50% sample of birth certificates were received from all registration areas and processed by NCHS. In 1972, some states began sending their data to NCHS through the Cooperative Health Statistics System (CHSS). States that participated in the CHSS program processed 100% of their death and birth records and sent the entire data file to NCHS on computer tapes. Currently, data are sent to NCHS through the Vital Statistics Cooperative Program (VSCP), following the same procedures as with CHSS. The number of participating states grew from 6 in 1972 to 46 in 1984. Starting in 1985, all 50 states and D.C. participated in VSCP.

##### U.S. Standard Certificates

U.S. Standard Certificates of Live Birth and Death and Fetal Death Reports are revised periodically, allowing evaluation and addition, modification, and deletion of items. Beginning with 1989, revised Standard Certificates replaced the 1978 versions. The 1989 revision of the birth certificate included items to identify the Hispanic parentage of newborns and to expand information about maternal and infant health characteristics. The 1989 revision of the death certificate included items on educational attainment and Hispanic origin of decedents, as well as changes to improve the medical certification of cause of death. Standard Certificates recommended by NCHS are modified in each registration area to serve the area’s needs. However, most certificates conform closely in content and arrangement to the Standard Certificate, and all certificates contain a minimum data set specified by NCHS. The 2003 revision of vital records went into effect in some states beginning in 2003, but full implementation in all states will be phased in over several years.

#### Birth File

##### Overview

Vital statistics natality data are a fundamental source of demographic, geographic, and medical and health information on all births occurring in the United States. This is one of the few sources of comparable health-related data for small geographic areas over an extended time period. The data are used to present the characteristics of babies and their mothers, track trends such as birth rates for teenagers, and compare natality trends with those in other countries.

##### Selected Content

The Birth file includes characteristics of the baby, such as sex, birthweight, and weeks of gestation; demographic information about the parents, such as age, race, Hispanic origin, parity, educational attainment, marital status, and state of residence; medical and health information, such as prenatal care, based on hospital records; and behavioral risk factors for the birth, such as mother’s tobacco use during pregnancy.

##### Data Years

The birth registration area began in 1915 with 10 states and the District of Columbia.

##### Methodology

In the United States, state laws require birth certificates to be completed for all births. The registration of births is the responsibility of the professional attendant at birth, generally a physician or midwife. The birth certificate must be filed with the local registrar of the district in which the birth occurs. Each birth must be reported promptly; the reporting requirements vary from state to state, ranging from 24 hours to as much as 10 days after the birth.

Federal law mandates national collection and publication of birth and other vital statistics data. NVSS is the result of cooperation between NCHS and the states to provide access to statistical information from birth certificates. Standard forms for the collection of the data, and model procedures for the uniform registration of the events, are developed and recommended for state use through cooperative activities of the states and NCHS. NCHS shares the costs incurred by the states in providing vital statistics data for national use.

##### Issues Affecting Interpretation

Data on mother’s educational attainment, tobacco use during pregnancy, and prenatal care based on the 2003 revision of the U.S. Standard Certificate of Live Birth are not comparable with data based on the 1989 revision of the U.S. Standard Certificate of Live Birth. Data on mother’s educational attainment, tobacco use during pregnancy, and prenatal care are shown only for the 21–22 reporting areas that used the 2003 revision in 2007–2008, in order to provide 2 years of comparable data. Data are not shown for reporting areas that were transitioning from the 1989 revision to the 2003 revision during 2007–2008 or for states that had other comparability issues with these three items during that timeframe. The 22 states that implemented the 2003 revision of the U.S. Standard Certificate of Live Birth as of January 1, 2007, are California, Colorado, Delaware, Florida, Idaho, Indiana, Iowa, Kansas, Kentucky, Nebraska, New Hampshire, New York state (excluding New York City), North Dakota, Ohio, Pennsylvania, South Carolina, South Dakota, Tennessee, Texas, Vermont, Washington, and Wyoming. California does not report information on tobacco use during pregnancy. In 2008, five more states—Georgia, New Mexico, Michigan, Montana, and Oregon—began using the 2003 revision. Approximately one-half (53%) of all births in 2007 and 65% of all births in 2008 were reported using the 2003 revision. Prior to 2003, the number of states reporting information on maternal education, Hispanic origin, marital status, and tobacco use during pregnancy increased over the years. Interpretation of trend data should take into consideration changes to reporting areas and immigration. For methodological and reporting area changes for the following birth certificate items, see Appendix II: Age; Cigarette smoking; Education; Hispanic origin; Marital status; Prenatal care; Race.

##### References

Vital Statistics of the United States 2000. Natality, Technical appendix. Hyattsville, MD. NCHS. 2002;I. Available from: http://www.cdc.gov/nchs/data/techap00.pdf.
Martin JA, Hamilton BE, Sutton PD, et al. Births: Final data for 2006. National vital statistics reports. Hyattsville, MD. NCHS. 2009;57(7). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr57/nvsr57_07.pdf.
Martin JA, Hamilton BE, Sutton PD, et al. Births: Final data for 2007. National vital statistics reports. Hyattsville, MD. NCHS. 2010;58(24). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_24.pdf.
Martin JA, Hamilton BE, Sutton PD, et al. Births: Final Data for 2008. National vital statistics reports. Hyattsville, MD. NCHS. 2010;59(1). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr59/nvsr59_01.pdf.

##### For More Information

See the Birth Data website at: http://www.cdc.gov/nchs/births.htm.

#### Fetal Death Data Set

##### Overview

Fetal mortality refers to the intrauterine death of a fetus at any gestational age. In Health, United States, data are presented for fetal deaths of 20 weeks or more. Fetal mortality is an important public health issue. There are nearly as many fetal deaths (of 20 weeks or more) as infant deaths in the United States each year.

##### Selected Content

The Fetal Death data set includes characteristics of the fetus, such as sex, birthweight, and weeks of gestation; demographic information about the parents, such as age, race, Hispanic origin, parity, educational attainment, marital status, and state of residence; medical and health information, such as prenatal care; and behavioral risk factors for the birth, such as mother’s tobacco use during pregnancy.

##### Data Years

Fetal mortality data reporting began in 1922.

##### Coverage

Data are reported by all 50 states and the District of Columbia.

##### Methodology

Fetal death means the death of a fetus prior to delivery from the mother, irrespective of the duration of pregnancy. Fetal deaths do not include induced terminations of pregnancy. This definition of fetal death, adopted by NCHS as the nationally recommended standard, is based on the definition published by the World Health Organization in 1950 and revised in 1988. The term fetal death encompasses other commonly used terms, including stillbirth, spontaneous abortion, and miscarriage. All U.S. states and registration areas have definitions similar to the standard definition, except for Puerto Rico and Wisconsin, which have no formal definition.

State laws require the reporting of fetal deaths, and federal law mandates national collection and publication of fetal death data. States and reporting areas submit fetal mortality data to NCHS as part of a cooperative agreement. Standard forms and procedures for the collection of the data are developed and recommended for state use through cooperative activities of the states and NCHS. NCHS shares the costs incurred by the states in providing vital statistics data for national use.

In addition to fetal mortality rates, perinatal mortality rates are also presented in Health, United States. Perinatal mortality includes both late fetal deaths (of at least 28 weeks of gestation) and early infant (neonatal) deaths (within 7 days of birth). Data on early infant deaths come from the Linked Birth/Infant Death data set.

##### Issues Affecting Interpretation

Reporting requirements for fetal deaths vary by state, and these differences have important implications for comparisons of fetal mortality rates by state. The majority of states require reporting of fetal deaths of 20 weeks of gestation or more, or a minimum of 350 grams birthweight (roughly equivalent to 20 weeks), or some combination of the two. However, seven states require reporting of fetal deaths of all periods of gestation, and one state requires reporting beginning at 16 weeks of gestation. Further, three states require the reporting of fetal deaths with birthweights of 500 grams or more (roughly equivalent to 22 weeks of gestation).

There is substantial evidence that not all fetal deaths for which reporting is required are, in fact, reported. Underreporting of fetal deaths is most likely to occur in the earlier part of the required reporting period for each state. For example, in 2005, for states which required the reporting of fetal deaths of all periods of gestation, 57% of fetal deaths at 20 weeks or more gestation occurred within 20–27 weeks, whereas for states that required reporting of fetal deaths of 500 grams or more, only 27% were within 20–27 weeks. This disparity suggests substantial underreporting of early fetal deaths in some states.

##### References

MacDorman MF, Kirmeyer S. Fetal and perinatal mortality, United States, 2005. National vital statistics report. Hyattsville, MD. NCHS. 2009;57(8). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr57/nvsr57_08.pdf.
MacDorman MF, Kirmeyer S. The challenge of fetal mortality. NCHS data brief no 16. Hyattsville, MD. NCHS. 2009. Available from: http://www.cdc.gov/nchs/data/databriefs/db16.pdf.

##### For More Information

See the NCHS Fetal Deaths data website at: http://www.cdc.gov/nchs/fetal_death.htm.

#### Mortality File

##### Overview

Vital statistics mortality data are a fundamental source of demographic, geographic, and cause-of-death information. This data set is one of the few sources of comparable health-related data for small geographic areas over an extended time period. The data are used to present the characteristics of those dying in the United States, to determine life expectancy, and to compare mortality trends with those in other countries.

##### Selected Content

The Mortality file includes demographic information on age, sex, race, Hispanic origin, state of residence, and educational attainment, as well as medical information on cause of death.

##### Data Years

The death registration area began in 1900 with 10 states and the District of Columbia.

##### Methodology

By law, the registration of deaths is the responsibility of the funeral director. The funeral director obtains demographic data for the death certificate from an informant. The physician in attendance at the death is required to certify the cause of death. Where death is from other than natural causes, a coroner or medical examiner may be required to examine the body and certify the cause of death. Data for the entire United States refer to events occurring within the United States; data for geographic areas are by place of residence. For methodological and reporting area changes for the following death certificate items, see Appendix II: Education; Hispanic origin; Race.

##### Issues Affecting Interpretation

The International Classification of Diseases (ICD), by which cause of death is coded and classified, is revised approximately every 10–20 years. Because revisions of the ICD may cause discontinuities in trend data by cause of death, comparison of death rates by cause of death across ICD revisions should be done with caution and with reference to the comparability ratio. (See Appendix II, Comparability ratio.) Prior to 1999, modifications to the ICD were made only when a new revision of the ICD was implemented. A process for updating the ICD was introduced with the 10th revision (ICD–10) that allows for mid-revision changes. These changes, however, may affect comparability of data between years for select causes of death. Minor changes may be implemented every year, whereas major changes may be implemented every 3 years (e.g., 2003 data year). In data year 2006, major changes were implemented, including the addition and deletion of several ICD codes. For more information, see Heron et al. (2009).

The death certificate has been revised periodically. A revised U.S. Standard Certificate of Death was recommended for state use beginning January 1, 1989. Among the changes were the addition of a new item on educational attainment and Hispanic origin of the decedent and changes to improve the medical certification of cause of death. The U.S. Standard Certificate of Death was revised again in 2003; states are adopting this new certificate on a rolling basis. As of 2008, 30 states and the District of Columbia (D.C.) had adopted the 2003 revision: Arkansas, California, Connecticut, Delaware, Florida, Georgia, Idaho, Illinois, Indiana, Kansas, Michigan, Montana, Nebraska, Nevada, New Hampshire, New Jersey, New Mexico, New York State (including New York City), North Dakota, Ohio, Oklahoma, Oregon, Rhode Island, South Carolina, South Dakota, Texas, Utah, Vermont, Washington, and Wyoming, and D.C. Mortality data presented in Health, United States are based on reporting from all 50 states and D.C.

The 2003 revision included significant changes in the way information on educational attainment and race are collected and coded. The educational attainment item was changed to be consistent with U.S. Census Bureau data and to improve the ability to identify specific types of educational degrees. Educational attainment data collected using the 2003 revision are not comparable with data collected using the 1989 revision. The 2003 revision also permits reporting of more than one race (multiple races). This change was implemented to reflect the increasing diversity of the U.S. population and to be consistent with the decennial census. Many states, however, are still using the 1989 revision of the U.S. Standard Certificate of Death which allows only a single race to be reported. Until all states adopt the new death certificate, the race data reported using the 2003 revision are “bridged” for those for whom more than one race was reported (multiple race) to one single race to provide comparability with race data reported on the 1989 revision. For more information on the impact of the 2003 certificate revisions on mortality data presented in Health, United States, including a list of states that have adopted the 2003 certificate, see Appendix II, Race.

##### References

Grove RD, Hetzel AM. Vital statistics rates in the United States, 1940–1960. Washington, DC. U.S. Government Printing Office. 1968.
Minino AM, Murphy SL, Xu JQ, Kochanek KD. Deaths: Final data for 2008. National vital statistics reports. Hyattsville, MD. NCHS. 2011;59(10). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr59/nvsr59_10.pdf.
NCHS. Vital Statistics of the United States. II. Mortality, part A, Technical appendix. Hyattsville, MD. NCHS. [published annually]. Available from: http://www.cdc.gov/nchs/products/vsus.htm#appendices.
Heron M, Hoyert DL, Murphy SL, et al. Deaths: Final data for 2006. National vital statistics reports. Hyattsville, MD. NCHS. 2009;57(14). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr57/nvsr57_14.pdf.

##### For More Information

See the Mortality Data website at: http://www.cdc.gov/nchs/deaths.htm.

#### Multiple Cause-of-Death File

##### Overview

Multiple cause-of-death data reflect all medical information reported on death certificates and complement traditional underlying cause-of-death data. Multiple-cause data give information on diseases that are a factor in death, whether or not they are the underlying cause of death; on associations among diseases; and on injuries leading to death.

##### Selected Content

In addition to the same demographic variables listed for the Mortality file, the Multiple Cause-of-Death file includes record axis and entity axis cause-of-death data (see Methodology, below).

##### Data Years

Multiple cause-of-death data files are available for every data year since 1968.

##### Methodology

NCHS is responsible for compiling and publishing annual national statistics on causes of death. In carrying out this responsibility, NCHS adheres to the World Health Organization (WHO) Nomenclature Regulations. These regulations require (a) that cause of death be coded in accordance with the applicable revision of the International Classification of Diseases (ICD) [see Appendix II, International Classification of Diseases (ICD); Table III]; and (b) that underlying cause of death be selected in accordance with international rules. Traditionally, national mortality statistics have been based on a count of deaths, with one underlying cause assigned for each death.

Prior to 1968, mortality medical data were based on manual coding of an underlying cause of death for each certificate, in accordance with WHO rules. Starting with 1968, NCHS converted to computerized coding of the underlying cause and manual coding of all causes (multiple causes) on the death certificate. In this system, called Automated Classification of Medical Entities (ACME), multiple cause codes serve as inputs to the computer software that employs WHO rules to select the underlying cause. ACME is used to select the underlying cause of death for all death certificates in the United States, and cause-of-death data in Health, United States are coded using ACME. In addition, NCHS has developed two computer systems as inputs to ACME. Beginning with 1990 data, the Mortality Medical Indexing, Classification, and Retrieval system (MICAR) was introduced to automate coding multiple causes of death. MICAR provides more detailed information on the conditions reported on death certificates than is available through the ICD code structure. Then, beginning with data year 1993, SuperMICAR, an enhancement of MICAR, was introduced.

SuperMICAR allows for literal entry of the multiple cause-of-death text as reported by the certifier. This information is then processed automatically by the MICAR and ACME computer systems. Records that cannot be processed automatically by MICAR or SuperMICAR are multiple-cause coded manually and then further processed through ACME. In 2006, SuperMICAR was used to process all of the Nation’s death records.

##### Issues Affecting Interpretation

The ICD, by which cause of death is coded and classified, is revised approximately every 10 to 15 years. Revisions of the ICD may cause discontinuities in trend data by cause of death; therefore, comparison of death rates by cause of death across ICD revisions should be done with caution and with reference to the comparability ratio. (See Appendix II, Comparability ratio.) Multiple-cause data were obtained from all certificates for 1968–1971, 1973–1980, and 1983–present. Data were obtained from a 50% sample of certificates for 1972. Multiple-cause data for 1981 and 1982 were obtained from a 50% sample of certificates from 19 registration areas. For the other states, data were obtained from all certificates.

##### Reference

NCHS. Multiple causes of death in the United States. Monthly vital statistics report. Hyattsville, MD. NCHS. 1984;32(10 suppl 2). Available from: http://www.cdc.gov/nchs/data/mvsr/supp/mv32_10s2.pdf.

##### For More Information

See the Mortality Multiple Cause data file website at: http://www.cdc.gov/nchs/data_access/Vitalstatsonline.htm.

#### Linked Birth/Infant Death Data Set

##### Overview

National linked files of live births and infant deaths are used for research on infant mortality.

##### Selected Content

The Linked Birth/Infant Death data set links information from the birth certificate to information from the death certificate for each infant death in the United States. The purpose of the linkage is to use the many additional variables from the birth certificate, including the more accurate race and ethnicity data, for more detailed analyses of infant mortality patterns. The Linked Birth/Infant Death data set includes all variables on the natality (Birth) file, including racial and ethnic information, birthweight, and maternal smoking, as well as variables on the Mortality file, including cause of death and age at death.

##### Data Years

National linked files of live births and infant deaths were first produced for the 1983 birth cohort. Birth cohort linked file data are available for 1983–1991, and both period linked files and birth cohort linked files are available starting with 1995. National linked files do not exist for 1992–1994.

##### Coverage

To be included in the U.S. linked file, both the birth and death must have occurred in the 50 states or the District of Columbia.

##### Methodology

Infant mortality rates are based on infant deaths per 1,000 live births. Infant deaths are defined as a death before the infant’s first birthday. About 97%–99% of infant death records can be linked to their corresponding birth certificates. The linkage makes available extensive information from the birth certificate about the pregnancy, maternal risk factors, infant characteristics, and health items at birth that can be used for more detailed analyses of infant mortality. The linked file is used for calculating infant mortality rates by race and ethnicity, which are more accurately measured from the birth certificate.

Starting with 1995 data, linked birth/infant death data files are available in two different formats: period data and birth cohort data. The numerator for the period linked file consists of all infant deaths occurring in a given data year linked to their corresponding birth certificates, whether the birth occurred in that year or the previous year. The numerator for the birth cohort linked file consists of deaths to infants born in a given year. In both cases, the denominator is all births occurring in the year. While the birth cohort format has methodological advantages, it creates substantial delays in data availability because it is necessary to wait until the close of the following data year to include all infant deaths to the birth cohort. Starting with 1995 data, period linked files are used for infant mortality rate tables in Health, United States.

The 2007 period linked file contains a numerator file that consists of all infant deaths occurring in 2007 that have been linked to their corresponding birth certificates, whether the birth occurred in 2006 or 2007. In contrast, the 2007 birth cohort linked file will contain a numerator file that consists of all infant deaths to babies born in 2007, whether the death occurred in 2007 or 2008.

Other changes to the data set starting with 1995 include the addition of record weights to compensate for the 1%–2% of infant death records that could not be linked to their corresponding birth records. In addition, not-stated birthweight was imputed if the period of gestation was known. This imputation was done to improve the accuracy of birthweight-specific infant mortality rates because the percentage of records with not-stated birthweight is generally higher for infant deaths (3.1% in 2007) than for live births (0.1% in 2007). In 2007, not-stated birthweight was imputed for 0.09% of births.

##### Issues Affecting Interpretation

Period linked file data starting with 1995 are not strictly comparable with birth cohort data for 1983–1991. A new revision of the birth certificate was introduced in 2003 and is being adopted by states on a voluntary, rolling basis. Data on mother’s educational attainment, tobacco use during pregnancy, and prenatal care based on the 2003 revision are not comparable with data based on the 1989 revision of the U.S. Standard Certificate of Live Birth. Data from the linked file for these three measures are not presented in Health, United States.

##### Reference

Mathews TJ, MacDorman MF. Infant mortality statistics from the 2007 period Linked Birth/Infant Death data set. National vital statistics report. Hyattsville, MD. NCHS. 2011;59(6). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr59/nvsr59_06.pdf.

##### For More Information

See the NCHS Linked Birth and Infant Death Data website at: http://www.cdc.gov/nchs/linked.htm.

#### Compressed Mortality File (CMF)

##### Overview

The CMF is a county-level national mortality and population database.

##### Selected Content

The CMF contains mortality data derived from the detailed Mortality files of the NVSS and estimates of U.S. national, state, and county resident populations from the U.S. Census Bureau. For 1968–1998, the number of deaths, crude death rates, and age-adjusted death rates can be obtained by place of residence (total U.S., state, and county), age group, race (white, black, and other), sex, year of death, and underlying cause of death. For 1999– 2007, mortality statistics can be obtained by place of residence, by age group and expanded race groups (white, black, American Indian or Alaska Native, Asian or Pacific Islander), and by Hispanic origin.

##### Data Years

The CMF spans the years 1968–2007. On CDC WONDER, data are available starting with 1979.

##### Methodology

In Health, United States, the CMF is used to compute death rates by urbanization level of the decedent’s county of residence. Counties are categorized according to level of urbanization based on the 2006 “NCHS Urban–Rural Classification Scheme for Counties” (available from: http://www.cdc.gov/nchs/data_access/urban_rural.htm). This scheme assigns counties and county equivalents to one of six urbanization levels: four metropolitan and two nonmetropolitan.

##### For More Information

See the CMF website at: http://www.cdc.gov/nchs/data_access/cmf.htm and the CDC WONDER website at: http://wonder.cdc.gov. (Also see Appendix II, Urbanization.)

### Occupational Employment Statistics (OES)

#### Bureau of Labor Statistics (BLS)

##### Overview

The OES program conducts a semiannual survey designed to produce estimates of employment and wages for specific occupations.

##### Selected Content

The OES survey produces estimates of occupational employment and wages for most three- and four-digit, and selected five-digit, North American Industry Classification System (NAICS) levels in these sectors: forestry and logging; mining; utilities; construction; manufacturing; wholesale trade; retail trade; transportation and warehousing; information; finance and insurance; real estate and rental and leasing; professional, scientific, and technical services; management of companies and enterprises; administrative and support and waste management and remediation services; educational services; health care and social assistance; arts, entertainment, and recreation; accommodation and food services; other services (except public administration); and federal, state, and local government.

##### Data Years

Prior to 1996, the OES program collected only occupational employment data for selected industries in each year of the 3-year survey cycle and produced only industry-specific estimates of occupational employment. The 1996 survey round was the first year that the OES program began collecting occupational employment and wage data in every state. In addition, the program’s 3-year survey cycle was modified to collect data from all covered industries each year. The year 1997 is the earliest year available for which the OES program produced estimates of cross-industry as well as industry-specific occupational employment and wages.

##### Coverage

The OES survey covers all full-time and part-time wage and salary workers in nonfarm establishments. Surveys collect data for the payroll period including the 12th day of May or November. The survey does not cover the self-employed, owners and partners in unincorporated firms, household workers, or unpaid family workers.

##### Methodology

The OES program surveys approximately 200,000 establishments per panel (every 6 months), taking 3 years to fully collect the sample of 1.2 million establishments. The estimates for occupations in nonfarm establishments are based on OES data collected for the reference months of May and November. May 2010 employment and wage estimates are based on all data collected from establishments sampled in the May 2010, November 2009, May 2009, November 2008, May 2008, and November 2007 semiannual panels. The May 2008 sample was reduced to approximately 174,000 establishments due to budget constraints. The overall national response rate for the six panels is 78% of establishments, covering 74% of employment. The OES survey is a federal–state cooperative program between BLS and state workforce agencies (SWAs). BLS provides the procedures and technical support, draws the sample, and produces the survey materials, while SWAs collect most of the data. SWAs from all 50 states plus the District of Columbia (D.C.), Puerto Rico, Guam, and the U.S. Virgin Islands participate in the survey. Occupational employment and wage rate estimates at the national level are produced by BLS using data from the 50 states and D.C. Employers who respond to states’ requests to participate in the OES survey make these estimates possible.

##### Issues Affecting Interpretation

The OES survey began using NAICS in 2002. In 2008, the survey switched to the 2007 NAICS classification system. Data prior to 2002 are based on the Standard Industrial Classification (SIC) system. In 1999, the OES survey began using the Office of Management and Budget (OMB) Standard Occupational Classification (SOC) system. Because of the OES survey’s transition to the SOC system, estimates for 1999 and subsequent years are not directly comparable with previous years’ estimates, which were based on a classification system having seven major occupational groups and 770 detailed occupations.

The May 2010 OES estimates mark the first set of estimates based in part on data collected using the 2010 SOC system, which consists of 840 detailed occupations grouped into 461 broad occupations, 97 minor groups, and 23 major groups. Previous estimates were based on the 2000 SOC. The OES program produces employment and wage estimates at the major group and detailed occupation level for 22 of the 23 SOC major groups. Major group 55, Military Specific Occupations, is not included. Although most occupations in the May 2010 OES estimates are 2010 SOC occupations, in some cases temporary codes were used. The May 2012 OES data will reflect the full set of detailed occupations in the 2010 SOC. For more information, see http://www.bls.gov/oes/oes_ques.htm#Ques41.

##### Reference

Bureau of Labor Statistics. Occupational employment and wages, May 2010. Washington, DC. U.S. Department of Labor. May. 2011.

##### For More Information

See the OES website at: http://www.bls.gov/OES.

### Online Survey Certification and Reporting Database (OSCAR)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

OSCAR is an administrative database containing detailed information on all Medicare- and Medicaid-certified institutional health care providers, including all currently and previously certified Medicare and Medicaid nursing homes, short-term hospitals, and intermediate care facilities for the mentally retarded in the United States and territories. (Data for the territories are not shown in Health, United States.) The purpose of the facility survey certification process is to ensure that facilities meet the current CMS care requirements and thus can be reimbursed for services furnished to Medicare and Medicaid beneficiaries.

##### Selected Content

OSCAR contains information on facility and patient characteristics and health deficiencies issued by the government during state surveys.

##### Data Years

OSCAR has been maintained by CMS [formerly the Health Care Financing Administration (HCFA)], since 1992. OSCAR is an updated version of the Medicare and Medicaid Automated Certification System that had been in existence since 1972.

##### Coverage

Facilities in the United States that receive Medicare or Medicaid payments are included.

##### Methodology

A facility representative fills out the forms with the required information, and the forms are submitted to CMS. The information provided can be audited at any time.

All certified facilities are inspected periodically by representatives of the state survey agency (generally the department of health). Some facilities are inspected twice, or more often, during any given reporting cycle. To avoid overcounting, the data must be edited and duplicates removed. Data editing and compilation of nursing home data were performed by Cowles Research Group (CRG) and published in the group’s Nursing Home Statistical Yearbook series. Data editing and compilation for other facilities were performed by NCHS staff.

##### References

Cowles CM, editor. Nursing home statistical yearbooks for 1995, 1996, and 1997. Anacortes, WA. Cowles Research Group. published 1995, 1997, and 1998, respectively.
Cowles CM, editor. Nursing home statistical yearbooks for 1998, 1999, 2000, 2001, and 2002. Washington, DC. American Association of Homes and Services for the Aging. published 1999, 2000, 2001, 2002, and 2003, respectively.
Cowles CM, editor. Nursing home statistical yearbooks for 2003–2010. McMinnville, OR. Cowles Research Group. published 2004–2011, respectively.
Centers for Medicare & Medicaid Services (CMS). Certification and compliance. Baltimore, MD. CMS. 2005. Available from: http://www.cms.gov/CertificationandComplianc/01_Overview.asp.

##### For More Information

See the CMS website at: http://www.cms.hhs.gov/NonIdentifiableDataFiles and the CRG website at: http://www.longtermcareinfo.com/index.html.

### Population Census and Population Estimates

#### U.S. Census Bureau

##### Decennial Census

The census of population (decennial census) has been held in the United States every 10 years since 1790. It has enumerated the resident population as of April 1 of the census year since 1930. Data on sex, race, Hispanic origin, age, and marital status are collected from 100% of the enumerated population. More detailed information such as income, education, housing, occupation, and industry are collected from a representative sample of the population.

#### Race Data on the 1990 Census

The question on race on the 1990 census was based on the Office of Management and Budget’s (OMB) 1977 Race and Ethnic Standards for Federal Statistics and Administrative Reporting (Statistical Policy Directive 15). This document specified rules for the collection, tabulation, and reporting of race and ethnicity data within the federal statistical system. The 1977 Standards required federal agencies to report race-specific tabulations using four single-race categories: American Indian or Alaska Native, Asian or Pacific Islander, black, and white. Under the 1977 Standards, race and ethnicity were considered to be two separate and distinct concepts. Thus, persons of Hispanic origin may be of any race.

#### Race Data on the 2000 Census

The question on race on the 2000 census was based on OMB’s 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity (Fed Regist 1997 October 30;62:58781–90). (Also see Appendix II, Race.) The 1997 Standards incorporated two major changes in the collection, tabulation, and presentation of race data. First, the 1997 Standards increased from four to five the minimum set of categories to be used by federal agencies for identification of race: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, and white. Second, the 1997 Standards included the requirement that federal data collection programs allow respondents to select one or more race categories when responding to a query on their racial identity. This provision means that there are potentially 31 race groups, depending on whether an individual selects one, two, three, four, or all five of the race categories. The 1997 Standards continue to call for use, when possible, of a separate question on Hispanic or Latino ethnicity and specify that the ethnicity question should appear before the question on race. Thus, under the 1997 Standards, as under the 1977 Standards, persons of Hispanic origin may be of any race.

#### Race Data on the 2010 Census

Like the race data on the 2000 census, the question on race on the 2010 census was based on OMB’s 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity (Fed Regist 1997 October 30;62:58781–90). (Also see Appendix II, Race.) The 1997 Standards required a minimum set of categories to be used by federal agencies for identification of race: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, and white and require that federal data collection programs allow respondents to select one or more race categories when responding to a query on their racial identity. The 1997 Standards continue to call for use, when possible, of a separate question on Hispanic or Latino ethnicity and specify that the ethnicity question should appear before the question on race. Thus, under the 1997 Standards, as under the 1977 Standards, persons of Hispanic origin may be of any race.

#### Modified Decennial Census Files

For several decades the U.S. Census Bureau has produced Modified Decennial Census files. These modified files incorporate adjustments to the 100% April 1 count data for (a) errors in the census data discovered subsequent to publication, (b) misreported age data, and (c) nonspecified race.

For the 1990 census, the U.S. Census Bureau modified the age, race, and sex data on the census and produced the Modified Age-Race-Sex (MARS) file. The differences between the population counts in the original census file and the MARS file are primarily due to modification of the race data. Of the 248.7 million persons enumerated in 1990, 9.8 million did not specify their race (over 95% were of Hispanic origin). For the 1990 MARS file, these persons were assigned the race reported by a nearby person with an identical response to the Hispanic origin question.

For the 2000 census, the U.S. Census Bureau modified the race data on the census and produced the Modified Race Data Summary file. For this file, persons who reported the category Some Other Race as part of their race response were assigned to one of the 31 race groups, which are the single- and multiple-race combinations of the five race categories specified in the 1997 OMB race and ethnicity standards. Persons who did not specify their race were assigned to one of the 31 race groups by imputation. Of the 18.5 million persons who reported the category Some Other Race as part of their race response, or who did not specify their race, 16.8 million (90.4%) were of Hispanic origin.

#### Bridged-race Population Estimates for Census 2000

Race data on the 2000 census are not comparable with race data on other data systems that are continuing to collect data using the 1977 Standards on race and ethnicity during the transition to full implementation of the 1997 Standards. For example, states are implementing the revised birth and death certificates—which have race and ethnicity items that are compliant with the 1997 Standards—at different times, and to date many states are still using the 1989 certificates that collect race and ethnicity data in accordance with the 1977 Standards. Thus, population estimates for 2000 and beyond with race categories comparable to the 1977 categories are needed so that race-specific birth and death rates can be calculated. To meet this need, NCHS, in collaboration with the U.S. Census Bureau, developed methodology to bridge the 31 race groups in Census 2000 to the four single-race categories specified under the 1977 Standards.

The bridging methodology was developed using information from the 1997–2000 National Health Interview Survey (NHIS). NHIS provides a unique opportunity to investigate multiple-race groups because, since 1982, it has allowed respondents to choose more than one race but has also asked respondents reporting multiple races to choose a primary race. The bridging methodology developed by NCHS involved the application of regression models relating person-level and county-level covariates to the selection of a particular primary race by the multiple-race respondents. Bridging proportions derived from these models were applied by the U.S. Census Bureau to the Census 2000 Modified Race Data Summary file. This application resulted in bridged counts of the April 1, 2000, resident single-race populations for four racial groups: American Indian or Alaska Native, Asian or Pacific Islander, black, and white. Because bridged-race population estimates continue to be needed for the calculation of vital rates, the Census Bureau annually produces postcensal bridged-race estimates of the July 1 resident single-race populations.

#### Reference

Ingram DD, Parker JD, Schenker N, et al. United States Census 2000 population with bridged race categories. Vital Health Stat. Hyattsville, MD. NCHS. 2003;2(135). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_135.pdf.

#### For More Information

See the NCHS website for U.S. Census Populations With Bridged Race Categories: http://www.cdc.gov/nchs/nvss/bridged_race.htm.

#### Postcensal Population Estimates

Postcensal population estimates are estimates made for the years following a census, before the next census has been taken. National postcensal population estimates are derived annually by updating the resident population enumerated in the decennial census using a components-of-population-change approach. Each annual series includes estimates for the current data year and revised estimates for the earlier years in the decade. The following formula is used to derive the estimates for a given year from those for the previous year, starting with the decennial census enumerated resident population as the base:

Resident population + births to U.S. resident women – deaths to U.S. residents + net international migration.

The postcensal estimates are consistent with official decennial census figures and do not reflect estimated decennial census underenumeration.

Estimates for the earlier years in a given series are revised to reflect changes in the components-of-change data sets (for example, births to U.S. resident women from a preliminary natality file are replaced with counts from a final natality file). To help users keep track of which postcensal estimate is being used, each annual series is referred to as a “vintage,” and the last year in the series is used to name the series. For example, the Vintage 2001 postcensal series has estimates for July 1, 2000, and July 1, 2001; and the Vintage 2002 postcensal series has revised estimates for July 1, 2000, and July 1, 2001, as well as estimates for July 1, 2002. The estimates for July 1, 2000, and for July 1, 2001, from the Vintage 2001 and Vintage 2002 postcensal series differ.

The U.S. Census Bureau also produces postcensal estimates of the resident population for each state and county by using a components-of-population-change method at the county level. An additional component of population change, net internal migration, is involved. The state population estimates are produced by summing all county populations within each state.

The Census Bureau has annually produced a postcensal series of estimates of the July 1 resident population of the United States based on Census 2000 by applying the components-of-change methodology to the Modified Race Data Summary file. These series of postcensal estimates have race data for 31 race groups, in accordance with the 1997 race and ethnicity standards. So that the race data for 2000-based postcensal estimates will be comparable with race data on vital records, the Census Bureau has applied the NHIS bridging methodology to each 31-race-group postcensal series of population estimates to obtain bridged-race postcensal estimates (estimates for the four single-race categories: American Indian or Alaska Native, Asian or Pacific Islander, black, and white). Bridged-race postcensal population estimates are available from: http://www.cdc.gov/nchs/nvss/bridged_race.htm.

Vital rates for 2000 were calculated using the bridged-race April 1, 2000, census counts, and vital rates for 2001 and beyond were calculated using bridged-race estimates of the July 1 population from the corresponding postcensal vintage.

#### Intercensal Population Estimates

Intercensal population estimates are estimates made for the years between two censuses and are produced once the decennial census at the end of the decade has been completed. They replace the postcensal estimates that were produced prior to the completion of the census at the end of the decade. Intercensal estimates are more accurate than postcensal estimates because they are based on both the census at the beginning and the census at the end of the decade and thus correct for the error of closure (the difference between the estimated population at the end of the decade and the census count for that date). The error of closure at the national level was quite small for the 1960s (379,000). However, for the 1970s it amounted to almost 5 million; for the 1980s, 1.5 million; and for the 1990s, about 6 million. The error of closure affects age, race, sex, and Hispanic origin subgroup populations differently, as well as the rates based on these populations. Vital rates that were calculated using postcensal population estimates are routinely revised when intercensal estimates become available.

Intercensal estimates for the 1990s with race data comparable to the 1977 Standards have been derived so that vital rates for the 1990s could be revised to reflect Census 2000. Calculation of the intercensal population estimates for the 1990s was complicated by the incomparability of the race data on the 1990 and 2000 censuses. The Census Bureau, in collaboration with National Cancer Institute and NCHS, derived race-specific intercensal population estimates for the 1990s using the 1990 Modified Age-Race-Sex (MARS) file as the beginning population base and the bridged-race population estimates for April 1, 2000, as the ending population base. Bridged-race intercensal population estimates are available from: http://www.cdc.gov/nchs/nvss/bridged_race.htm.

Some intercensal population estimates using the data from the 2010 census have been released but have not yet been incorporated into vital statistics rates in Health, United States.

##### For More Information

See the U.S. Census Bureau website at: http://www.census.gov.

### Sexually Transmitted Disease (STD) Surveillance

#### CDC/National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention (NCHHSTP)

##### Overview

Surveillance information on the incidence and prevalence of STDs is used to inform public and private health efforts to control these diseases.

##### Selected Content

Case reporting data are available for nationally notifiable chancroid, chlamydia, gonorrhea, and syphilis. Surveillance of other STDs, such as genital herpes simplex virus, genital warts or other human papillomavirus infections, and trichomoniasis are based on estimates of office visits in physician office practices provided by the National Disease and Therapeutic Index.

##### Data Years

STD national surveillance data have been collected since 1941.

##### Coverage

Case reports of STDs are reported to CDC by STD surveillance systems operated by state and local STD control programs and health departments in 50 states, the District of Columbia, selected cities, 3,141 U.S. counties, and outlying areas consisting of U.S. dependencies, possessions, and independent nations in free association with the United States. Data from outlying areas are not included in Health, United States.

##### Methodology

Information is obtained from the following data sources: (a) case reports from STD project areas; (b) prevalence data from the Regional Infertility Prevention Project, the National Job Training Program (formerly the Job Corps), the Corrections STD Prevalence Monitoring Projects, and the Men Who Have Sex With Men Prevalence Monitoring Project; (c) sentinel surveillance of gonococcal antimicrobial resistance from the Gonococcal Isolate Surveillance Project; and (d) national sample surveys implemented by federal and private organizations. STD data are submitted to CDC on a variety of hard-copy summary reporting forms (monthly, quarterly, and annually) and in electronic summary or individual case-specific (line-listed) formats via the National Electronic Telecommunications System for Surveillance.

##### Issues Affecting Interpretation

Because of incomplete diagnosis and reporting, the number of STD cases reported to CDC undercounts the actual number of cases occurring among the U.S. population.

##### Reference

CDC. Sexually transmitted diseases surveillance, 2009. Atlanta, GA. CDC, Division of STD Prevention. 2010. Available from: http://www.cdc.gov/std/stats09/default.htm.

##### For More Information

See the STD Surveillance Report website at: http://www.cdc.gov/std/stats and the STD website at: http://www.cdc.gov/std/default.htm.

### Surveillance, Epidemiology, and End Results Program (SEER)

#### National Cancer Institute (NCI)

##### Overview

SEER tracks the incidence of new cancers each year and collects follow-up information on all previously diagnosed patients until their death.

##### Selected Content

For each cancer, SEER registries routinely collect data on patient demographics, primary tumor site, morphology, stage at diagnosis, first course of treatment, and follow-up for vital status.

##### Data Years

Case ascertainment for SEER began January 1, 1973, and has continued for more than 38 years. The most recent data available are for 2008.

##### Coverage

The SEER 9 registries (Atlanta, Connecticut, Detroit, Hawaii, Iowa, New Mexico, San Francisco– Oakland, Seattle–Puget Sound, and Utah) have been part of the program continuously since 1975. The SEER 13 registries (the SEER 9 registries plus Los Angeles, San Jose–Monterey, rural Georgia, and the Alaska Native Tumor Registry) have been part of the program continuously since 1992. The SEER 17 registries (the SEER 13 plus Kentucky, Greater California, New Jersey, and Louisiana) have been part of the program continuously since 2000. SEER currently collects and publishes cancer incidence and survival data from 17 population-based cancer registries covering approximately 26% of the U.S. population.

To ensure continuity in reporting areas for trend data, the SEER data file is commonly used both for statistical analyses and for analysis of cancer survival rates in Health, United States. The SEER 13 data file is commonly used for analysis of cancer incidence by expanded racial and ethnic groups.

##### Methodology

A cancer registry collects and stores data on cancers diagnosed in a specific hospital or medical facility (hospital-based registry) or in a defined geographic area (population-based registry). A population-based registry includes, but is not limited to, a number of hospital-based registries. In SEER registry areas, trained coders abstract medical records using the International Classification of Diseases for Oncology, 3rd Edition (ICD–O–3), which provides coding systems for site and tumor morphology. The third edition, implemented in 2001, is the first complete review and revision of the text and guidelines since the original publication in 1988. The major staging systems used by cancer registries are American Joint Committee on Cancer TNM (tumor, nodes, metastasis) staging and SEER Summary Stage. The SEER Extent of Disease (EOD) and TNM stages include schemes for all sites and morphologies and are used by NCI to derive SEER Summary Stage and Collaborative Staging.

NCI obtains population counts from the U.S. Census Bureau and uses them to calculate incidence rates. It also uses estimation procedures as needed to obtain estimates for years and races not included in data provided by the Census Bureau. Life tables used to determine general population life expectancy when calculating relative survival rates were obtained from NCHS and in-house calculations. Separate life tables are used for each race-sex-specific group included in SEER.

##### Issues Affecting Interpretation

Because of the addition of registries over time, analysis of long-term incidence and survival trends is limited to those registries that have been in SEER for similar lengths of time. Analysis of Hispanic and American Indian and Alaska Native data is limited to shorter trends. Starting with Health, United States, 2006, the North American Association of Central Cancer Registries (NAACCR) Hispanic Identification Algorithm was used on a combination of variables to classify cases as Hispanic for analytic purposes. Starting with Health, United States, 2007, Hispanic incidence data exclude data for Alaska. Earlier editions of Health, United States also excluded Hispanic data for Hawaii and Seattle. Starting with Health, United States, 2007, incidence estimates for the American Indian or Alaska Native population are limited to contract health service delivery area (CHSDA) counties within SEER reporting areas. This change is believed to produce estimates that more accurately reflect the incidence rates for this population group. More information on CHSDA is available from: http://www.ihs.gov/nonmedicalprograms/chs/index.cfm. For more information on SEER estimates by race and ethnicity, see: http://seer.cancer.gov/seerstat/variables/seer/race_ethnicity/index.html. Rates presented in this report may differ somewhat from those reported previously due to changes in population estimates and the addition and deletion of small numbers of incidence cases.

##### Reference

Howlader N, Noone AM, Krapcho M, Neyman N, Aminou R, Waldron W, et al., editors. SEER cancer statistics review, 1975–2008. (Based on November 2010 SEER data submission). Bethesda, MD. National Cancer Institute. 2011. Available from: http://seer.cancer.gov/csr/1975_2008/.

##### For More Information

See the SEER website at: http://seer.cancer.gov.

### Survey of Occupational Injuries and Illnesses (SOII)

#### Bureau of Labor Statistics (BLS)

##### Overview

SOII is a federal and state program that collects statistics used to identify problems with workplace safety and to develop programs to improve workplace safety. Occupational Safety and Health Administration (OSHA) regulations require the recording and reporting by employers of occupational fatalities, injures, and illnesses. Each January, a sample of employers is selected by BLS to participate in a mandatory SOII for that calendar year.

##### Selected Content

Data include the number of new nonfatal injuries and illnesses by industry. The case and demographic data provide additional details on workers injured, the nature of the disabling condition, and the event and source producing that condition for those cases that involve one or more days away from work.

##### Data Years

BLS has conducted an annual survey since 1971.

##### Coverage

The data represent persons employed in private industry establishments in the United States. The survey excludes the self-employed, farms with fewer than 11 employees, private households, and federal government agencies. BLS produces annual estimates of injuries and illnesses for many of the two-, three-, four-, five-, and six-digit private-sector industries as defined by the North American Industry Classification System (NAICS).

##### Methodology

Survey estimates of occupational injuries and illnesses are based on a scientifically selected probability sample of establishments, rather than a census of all establishments. Each January, an independent sample of establishments is selected for each state and the District of Columbia to participate in the mandatory SOII. BLS includes all the state samples in the national sample.

Establishments included in the survey are instructed to maintain lists of injuries and illnesses and to track days away from work, restricted, or transferred for the calendar year, using the OSHA Summary of Work-Related Injuries and Illnesses form (OSHA no 300A). In January following the year of data collection, BLS mails this sample of employers the SOII. An occupational injury is any injury, such as a cut, fracture, sprain, or amputation, that results from a work-related event or from a single instantaneous exposure in the work environment. An occupational illness is any abnormal condition or disorder, other than one resulting from an occupational injury, caused by exposure to factors associated with employment. It includes acute and chronic illnesses or diseases that may be caused by inhalation, absorption, ingestion, or direct contact. Prior to 2002, injury and illness cases involved days away from work, days of restricted work activity, or both (lost workday cases). Starting in 2002, injury and illness cases may involve days away from work, job transfer, or restricted work activity. Restriction may involve shortened hours, a temporary job change, or temporary restrictions on certain duties (for example, no heavy lifting) of a worker’s regular job.

##### Sample Size and Response Rate

Employer reports were collected from about 198,300 private industry establishments in 2009. Not all establishments included in the survey return the survey. The survey response rate was 91% in 2009.

##### Issues Affecting Interpretation

The number of new injuries and illnesses reported in any given year can be influenced by the level of economic activity, working conditions and work practices, worker experience and training, and number of hours worked. Long-term latent illnesses caused by exposure to carcinogens are believed to be understated in the survey’s illness measures. In contrast, new illnesses such as contact dermatitis and carpal tunnel syndrome are easier to relate directly to workplace activity.

Effective January 1, 2002, OSHA revised its requirement for recording occupational injuries and illnesses. Because of the revised recordkeeping rule, the estimates from the 2002 survey and beyond are not comparable with those from previous years. See http://www.osha.gov/recordkeeping/index.html for details on the revised recordkeeping requirements.

Data for the mining industry and for railroad activities are provided by the Department of Labor’s Mine Safety and Health Administration and the Department of Transportation’s Federal Railroad Administration. Neither of these agencies adopted the revised OSHA recordkeeping requirements for 2002. Therefore, estimates for these industries for 2002 and beyond are not comparable with estimates for other industries but are comparable with estimates for prior years. Excluded from the survey are self-employed individuals, farmers with fewer than 11 employees, private households, federal government agencies, and employees in state and local government agencies.

Starting with 2003 data, SOII began using NAICS to classify industries. Prior to 2003, the program used the Standard Industrial Classification (SIC) system and the Bureau of the Census occupational classification system. Although some titles in SIC and NAICS are similar, there is limited compatibility because industry groupings are defined differently in the two systems. (See Appendix II, Industry of employment.)

##### Reference

Bureau of Labor Statistics. Workplace injuries and illnesses—2009 [press release]. USDL pub no 10–1451. Washington, DC. U.S. Department of Labor. 2010. October. 21. Available from: http://www.bls.gov/news.release/archives/osh_10212010.htm.

##### For More Information

See the SOII website at: http://www.bls.gov/iif/home.htm and the SOII section of the BLS Handbook of Methods at: http://www.bls.gov/opub/hom/homch9.htm#scope_SOII.

### United States Renal Data System (USRDS)

#### National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK), in conjunction with the Centers for Medicare & Medicaid Services (CMS) and the Health Resources and Services Administration (HRSA)

##### Overview

USRDS is a national data system that collects, analyzes, and distributes information about end-stage renal disease (ESRD) in the United States. USRDS staff collaborate with staff from CMS, HRSA, the Organ Procurement and Transplantation Network (OPTN) under the auspices of HRSA, and the ESRD networks, sharing data sets and actively working to improve the accuracy of ESRD patient information. USRDS has five goals: (a) to characterize the ESRD population; (b) to describe the prevalence and incidence of ESRD, along with trends in mortality and disease rates; (c) to investigate relationships among patient demographics, treatment modalities, and morbidity; (d) to identify new areas for special renal studies and support investigator-initiated research; and (e) to provide data sets and samples of national data to support research by the Special Studies Centers.

##### Selected Content

USRDS maintains a stand-alone database with data on the diagnoses and demographic characteristics of ESRD patients, along with biochemical data, dialysis claims, and information on treatment and payer histories, hospitalization events, deaths, physician and supplier services, and providers.

##### Data Years

Data have been compiled annually since 1988.

##### Coverage

The primary source of ESRD identification is the ESRD Medical Evidence form that is used to register patients at the onset of ESRD and that must be submitted by dialysis or transplant providers within 45 days of initiation. The form establishes Medicare eligibility for individuals previously not Medicare beneficiaries, reclassifies previously eligible beneficiaries as ESRD patients, and provides demographic and diagnostic information on all new patients. The CMS, USRDS, and renal research communities rely on the form to ascertain patient demographics, primary diagnosis, comorbidities, and biochemical test results at the time of ESRD initiation. Since 1995, providers have been required to complete the form for all new ESRD patients (Medicare and non-Medicare eligible).

##### Methodology

Data for the USRDS database are compiled from existing data sources including the CMS Renal Management Information System (REMIS), CMS claims data, facility survey data, CDC survey data [National Health and Nutrition Examination Survey (NHANES)], Standard Information Management System (SIMS), Medicare Evidence form (CMS–2728), ESRD Death Notification form (CMS–274 6), and OPTN transplant and wait-list data. The CMS data files are supplemented by CMS with enrollment, payer history, and other administrative data, to provide utilization and demographic information on ESRD patients.

##### Sample Size and Response Rate

Response or coverage rates are 100% of people treated for ESRD since May 1995 because the amended ESRD entitlement policy requires a Medicare Evidence form to be submitted for all ESRD patients, regardless of their insurance and eligibility status. However, the payment data for non-Medicare ESRD patients may be absent during the 30-month coordination period. Ascertainment of incident cases may also be incomplete because the data are for persons receiving ESRD treatment as reported to CMS and do not include patients who die of ESRD before receiving treatment and those who are not reported to CMS.

##### For More Information

See the USRDS website at: http://www.usrds.org.

### Youth Risk Behavior Survey (YRBS)

#### CDC/National Center for Chronic Disease Prevention and Health Promotion (NCCDPHP)

##### Overview

YRBS monitors health risk behaviors among students in grades 9–12 that contribute to morbidity and mortality in both adolescence and adulthood.

##### Selected Content

Data are collected on behaviors that contribute to unintentional injuries and violence; tobacco use; alcohol and other drug use; sexual behaviors that contribute to unintended pregnancy and sexually transmitted diseases (STDs), including human immunodeficiency virus (HIV) infection; unhealthy dietary behaviors; and physical inactivity. In addition, YRBS monitors the prevalence of obesity and asthma.

##### Data Years

The national YRBS of high school students was conducted in 1990, 1991, 1993, 1995, 1997, 1999, 2001, 2003, 2005, 2007, 2009, and 2011 (scheduled for release in summer 2012).

##### Coverage

Data are representative of high school students in public and private schools in the United States.

##### Methodology

The national YRBS school-based surveys employ a three-stage cluster sample design to produce a nationally representative sample of students in grades 9–12 attending public and private high schools. The first-stage sampling frame contains primary sampling units (PSUs) consisting of large counties or groups of smaller, adjacent counties. The PSUs are then stratified based on degree of urbanization and relative percentage of black and Hispanic students in the PSU. The PSUs are selected from these strata with probability proportional to school enrollment size. At the second sampling stage, schools are selected with probability proportional to school enrollment size. To enable separate analysis of data for black and Hispanic students, schools with substantial numbers of black and Hispanic students are sampled at higher rates than all other schools. The third stage of sampling consists of randomly selecting one or two intact classes of a required subject from grades 9 through 12 at each chosen school. All students in the selected classes are eligible to participate in the survey. A weighting factor is applied to each student record to adjust for nonresponse and for the varying probabilities of selection, including those resulting from the oversampling of black and Hispanic students.

##### Sample Size and Response Rate

The sample size for the 2009 YRBS was 16,460 students in 158 schools. The school response rate was 81%, and the student response rate was 88%, for an overall response rate of 71%.

##### Issues Affecting Interpretation

National YRBS data are subject to at least two limitations. First, these data apply only to adolescents who attend regular high school. These students may not be representative of all persons in this age group because those who have dropped out of high school or attend an alternative high school are not surveyed. Second, the extent of underreporting or overreporting cannot be determined, although the survey questions demonstrate good test–retest reliability.

Estimates of substance use for youth based on YRBS differ from the National Survey on Drug Use & Health (NSDUH) and the Monitoring the Future (MTF) Study. Rates are not directly comparable across these surveys because of differences in populations covered, sample design, questionnaires, and interview setting. NSDUH collects data in residences, whereas MTF and YRBS collect data in school classrooms. In addition, NSDUH estimates are tabulated by age, whereas MTF and YRBS estimates are tabulated by grade, representing different ages as well as different populations.

##### References

CDC. Methodology of the Youth Risk Behavior Surveillance System. MMWR. 2004;53(RR–12):1-13. Available from: http://www.cdc.gov/mmwr/PDF/rr/rr5312.pdf.
Eaton DK, Kann L, Kinchen S, Shanklin S, Ross J, Hawkins J, et al. Youth Risk Behavior Surveillance—United States, 2009. MMWR Surveill Summ. 2010;59(SS–5):1-142. Available from: http://www.cdc.gov/mmwr/PDF/ss/ss5905.pdf.
Cowan CD. Coverage, sample design, and weighting in three federal surveys. J Drug Issues. 2001;31(3):599-614.

##### For More Information

See the YRBS website at: http://www.cdc.gov/yrbs.

## Private and Global Sources

### American Association of Colleges of Osteopathic Medicine (AACOM)

AACOM, founded in 1898, compiles data on various aspects of osteopathic medical education for distribution to the profession, the government, and the public. Questionnaires are sent annually to schools of osteopathic medicine requesting information on characteristics of applicants, students and graduates, faculty, curriculum, contract and grant activity, revenues and expenditures, and clinical facilities. The response rate is 96% for the 2007–2008 survey year.

#### Reference

American Association of Colleges of Osteopathic Medicine (AACOM). A report on a survey of Osteopathic Medical School Growth, 2007–2008. Chevy Chase, MD. AACOM. 2008.

#### For More Information

Contact the American Association of Colleges of Osteopathic Medicine, 5550 Friendship Boulevard, Suite 310, Chevy Chase, MD 20815; or see the AACOM website at: http://www.aacom.org.

### American Association of Colleges of Pharmacy (AACP)

AACP compiles data on colleges and schools of pharmacy, including information on student enrollment and types of degrees conferred. Data are collected through an annual survey. In 2009, the response rate was 100%.

#### Reference

American Association of Colleges of Pharmacy (AACP). Profile of pharmacy students: Fall 2009. Alexandria, VA. AACP. 2010.

#### For More Information

Contact the American Association of Colleges of Pharmacy, 1727 King Street, Alexandria, VA 22314; or see the AACP website at: http://www.aacp.org.

### American Association of Colleges of Podiatric Medicine (AACPM)

AACPM compiles data on colleges of podiatric medicine, including information on the schools and enrollment. Data are collected annually through written questionnaires. The response rate is 100%.

#### Reference

American Association of Colleges of Podiatric Medicine. Applicant, matriculant, and graduate statistics. Available from: http://www.aacpm.org.

#### For More Information

Contact the American Association of Colleges of Podiatric Medicine, 15850 Crabbs Branch Way, Suite 320, Rockville, MD 20855; or see the AACPM website at: http://www.aacpm.org.

### American Dental Association (ADA)

ADA’s Division of Educational Measurement conducts annual surveys of predoctoral dental educational institutions. A questionnaire, mailed to all dental schools, collects information on academic programs, admissions, enrollment, attrition, graduates, educational expenses and financial assistance, patient care, advanced dental education, and faculty positions.

#### Reference

American Dental Association (ADA). 2009–2010 Survey of dental education. Academic programs, enrollment, and graduates. Chicago, IL. ADA. 2011;1. Available from: http://www.ada.org/1621.aspx.

#### For More Information

Contact the American Dental Association, 211 East Chicago Avenue, Chicago, IL 60611; or see the ADA website at: http://www.ada.org.

### American Hospital Association (AHA) Annual Survey of Hospitals

Data from the AHA’s annual survey are based on questionnaires sent to all AHA-registered and nonregistered hospitals in the United States and its associated areas: American Samoa, Guam, the Marshall Islands, Puerto Rico, and the Virgin Islands. U.S. government hospitals located outside the United States are excluded. Overall, the average response rate over the past 5 years has been approximately 83%. For nonreporting hospitals and for the survey questionnaires of reporting hospitals on which some information was missing, estimates are made for all data except those on beds, bassinets, facilities, and services. Data for beds and bassinets of nonreporting hospitals are based on the most recent information available from those hospitals. Data for facilities and services are based only on reporting hospitals.

Estimates of other types of missing data are based on data reported the previous year, if available. When unavailable, estimates are based on data furnished by reporting hospitals similar in size, control, major service provided, length of stay, and geographic and demographic characteristics.

#### For More Information

Contact the AHA Annual Survey of Hospitals, Health Forum, LLC, an American Hospital Association Company, One North Franklin Street, Chicago, IL 60606; or see the AHA website at: http://www.aha.org.

### American Medical Association (AMA) Physician Masterfile

A master file of physicians has been maintained by the AMA since 1906. The Physician Masterfile contains data on all physicians in the United States, both members and nonmembers of the AMA, and on those graduates of American medical schools temporarily practicing overseas. The file also includes information on international medical graduates (IMGs) who are graduates of foreign medical schools, who reside in the United States, and who meet U.S. educational standards for primary recognition as physicians.

A file is initiated on each individual upon entry into medical school or, in the case of IMGs, upon entry into the United States. Between 1969 and 1985, a mail questionnaire survey was conducted every 4 years to update the file information on professional activities, self-designated area of specialization, and present employment status. Between 1985 and 2006, approximately one-third to one-fourth of all physicians are surveyed each year. Since then, the AMA has employed a more diversified survey approach in which more than 500,000 active physicians are targeted each year via mail, telephone, and Web-based surveys.

#### Reference

American Medical Association (AMA), Division of Survey and Data Resources. Physician characteristics and distribution in the U.S., 2011. Chicago, IL. AMA. 2011.

#### For More Information

Contact the American Medical Association, 515 North State Street, Chicago, IL 60654; or see the AMA website at: http://www.ama-assn.org.

### American Osteopathic Association (AOA)

AOA was established to promote the public health, to encourage scientific research, and to maintain and improve high standards of medical education in osteopathic colleges. The AOA Department of Educational Affairs sets the standards for and accredits osteopathic medical colleges and hospitals, postdoctoral training, and board certification programs. AOA publishes both professional and public informational materials. Professional publications include information on osteopathic education, accreditation of hospitals and other health care delivery facilities, and physician licensing. Public information materials include introductory materials on osteopathic medicine, brochures on osteopathic physicians and osteopathic medicine, and patient education materials. AOA compiles the number of osteopathic physicians (DOs); the number of active DOs by gender, age, and specialty and by 50 states and the District of Columbia; and the number of osteopathic medical students by selected characteristics.

#### Reference

American Osteopathic Association (AOA). Osteopathic medical profession report, 2009. Chicago, IL. AOA. 2011. Available from: http://www.osteopathic.org/inside-aoa/about/who-we-are/Documents/Osteopathic-Medical-Profession-Report-2009.pdf.

#### For More Information

Contact the American Osteopathic Association, 142 East Ontario Street, Chicago, IL 60611; or see the AOA website at: http://www.osteopathic.org.

### Association of American Medical Colleges (AAMC)

AAMC collects information on student enrollment in medical schools through its annual Liaison Committee on Medical Education questionnaire, the fall enrollment questionnaire, and the American Medical College Application Service (AMCAS) data system. Other data sources are the Medical School Profile System, the Pre-MCAT questionnaire, the Minority Student Opportunities in Medicine questionnaire, the Faculty Roster system, data from the Medical College Admission Test, and one-time surveys developed for special projects.

The AAMC Data Warehouse (DW) stores two sections of data relevant to applicants and students: AAMC DW: AMF (Applicant Matriculant file) and AAMC DW: Student. From these two source files, AAMC derives summary statistics about applicants, accepted applicants, matriculants, enrollees, and graduates. AAMC DW: AMF compiles applicant and matriculant data from AMCAS and other medical school application processes. AAMC DW: Student compiles enrollee and graduate data from the AAMC Student Records System. Applicant, enrollment, and graduate statistical data are arranged by academic year, which begins July 1 and ends June 30.

#### Reference

Association of American Medical Colleges (AAMC). AAMC data book: Medical schools and teaching hospitals by the numbers, 2011. Washington, DC. AAMC. 2011.

#### For More Information

Contact the Association of American Medical Colleges, 2450 N Street, NW, Washington, DC 20037; or see the AAMC website at: http://www.aamc.org.

### Association of Schools and Colleges of Optometry (ASCO)

ASCO compiles data on various aspects of optometric education, including data on schools and enrollment. Schools and colleges complete an annual questionnaire. The response rate is 100%.

#### Reference

Association of Schools and Colleges of Optometry (ASCO). Annual survey of optometric educational institutions: 2009–2010. Rockville, MD. ASCO. 2011.

#### For More Information

Contact the Association of Schools and Colleges of Optometry, 6110 Executive Boulevard, Suite 420, Rockville, MD 20852; or see the ASCO website at: http://www.opted.org.

### Association of Schools of Public Health (ASPH)

ASPH compiles data on schools of public health in the United States and Puerto Rico. Unlike health professional schools that emphasize specific clinical occupations, schools of public health offer study in specialty areas such as biostatistics, epidemiology, environmental health, occupational health, health administration, health planning, nutrition, maternal and child health, social and behavioral sciences, and other population-based sciences. Questionnaires are sent annually to all member schools. The response rate is 100%.

#### Reference

Association of Schools of Public Health (ASPH). Annual data report, 2010. Washington, DC. ASPH. 2011. Available from: http://www.asph.org/UserFiles/DataReport2010.pdf.

#### For More Information

Contact the Association of Schools of Public Health, 1101 15th Street NW, Suite 910, Washington, DC 20005; or see the ASPH website at: http://www.asph.org.

### Computed Tomography (CT) and Magnetic Resonance Imaging (MRI) Census

The CT/MRI Census is a biennial telephone survey that queries all hospital and nonhospital sites in the United States performing CT and MRI procedures. The census details the types of procedures being performed, procedure volumes, staffing and productivity, installed equipment, planned equipment purchases, and annual budgets for consumables, including contrast media.

Candidate sites for MRI/CT procedures are identified in the American Hospital Association’s AHA Guide. U.S. territories are not included.

#### References

American Hospital Association (AHA). AHA guide, 2010. Chicago, IL. AHA. 2009.
IMV, Medical Information Division. 2007. Computed tomography (CT) and magnetic resonance imaging (MRI) census, benchmark report: Installed base of CT scanners; Installed base of MRI scanners. Des Plaines, IL. IMV Ltd., Medical Information Division. 2008.

#### For More Information

Contact IMV, 6301 Ivy Lane, Suite 204, Greenbelt, MD 20770; or see the IMV website at: http://www.imvinfo.com/index.aspx?sec=def.

### Guttmacher Institute Abortion Provider Census

The Guttmacher Institute (previously called the Alan Guttmacher Institute, or AGI) is a not-for-profit organization for reproductive health research, policy analysis, and public education. The Institute’s abortion provider surveillance program documents the number of legal induced abortions, monitors unintended pregnancy, and assists in efforts to identify and reduce preventable causes of morbidity and mortality associated with abortions. Guttmacher has collected or estimated national abortion data since 1973. Fifteen provider surveys have been conducted for selected data years 1973–2009. Guttmacher reports the number of induced abortions and the number, types, and locations of abortion providers by state and region. Health, United States presents the total number of abortions reported by Guttmacher for each data year.

The abortion data reported to Guttmacher include women of all ages, including adolescents, who obtain legal induced abortions, and includes both surgical and medication (e.g., using mifepristone, misoprostol, or methotrexate) abortion procedures. Data are collected from three major categories of providers that were identified as potential providers of abortion services: clinics, physicians, and hospitals. For the 2009 data, the distributor of mifepristone also mailed surveys to all facilities and medical professionals that had ever purchased mifepristone (which was approved for use in medical abortion in 2000).

A version of the 2009 survey questionnaire was created for each of the three major categories of providers, modeled on the survey questionnaire used for Guttmacher’s data collection in 2004–2005. Questionnaires were mailed to all potential providers, with two additional mailings and telephone follow-up for nonresponse. All surveys asked the number of induced abortions performed at the provider’s location. State health statistics agencies were also contacted, requesting all available data reported by providers to each state health agency on the number of abortions performed in the survey year. For states that provided data to The Guttmacher Institute, the health agency figures were used for providers who did not respond to the survey. Estimates of the number of abortions performed by some providers were ascertained from knowledgeable sources in the community. Of the 2,344 potential providers surveyed for 2009 data, 1,525 responded directly or in follow-up; health department data were used for 451 providers; knowledgeable sources were used for 109 providers; and Guttmacher made its own estimates for 230 facilities. The level of internal estimation was higher than in previous years because health department data from New York and California were less complete.

To estimate the number of abortions performed in 2001, 2002, and 2003, the Guttmacher Institute first estimated the change in the number of abortions between 2000 and 2001, beginning with the number of abortions occurring in each state, as reported by CDC, in each of those 2 years (see Appendix I, Abortion Surveillance System). The three states without reporting systems were excluded. Guttmacher also eliminated the states with very incomplete or inconsistent reporting [Arizona, Maryland, Nevada, and the District of Columbia (D.C.)] and summed the number of abortions that took place in the 44 remaining states for each year. The percentage change between 2000 and 2001 was then applied to Guttmacher’s more complete nationwide count of 1,312,990 abortions in 2000 to arrive at the national estimate for 2001. The same procedure was used to estimate the change in the number of abortions between 2001 and 2002 and between 2002 and 2003, except that the data for both years were collected directly from state health departments because the CDC abortion surveillance report for the latest year was not yet available. The states without reporting systems were not included, and, as before, Guttmacher excluded states with incomplete or inconsistent reporting. Further adjustments were made after the 2004–2005 Guttmacher survey results became available.

The CDC national count of abortions was 15% lower than the Guttmacher survey in 1977 and 1978, 12% lower in 1987, 11% lower in 1991 and 1992, and 12% lower in 1995. Beginning in 1998, CDC reported totals for only 48 states and D.C.; since then, the total number of abortions reported to CDC has been about 34% less than the total estimated by Guttmacher. The three reporting areas that did not report abortions to CDC in 2005 (the largest of which was California) accounted for 18% of all abortions tallied by Guttmacher’s 2005 survey. (See Appendix I, Abortion Surveillance System.)

#### References

Finer LB, Henshaw SK. Abortion incidence and services in the United States in 2000. Perspect Sex Reprod Health. 2003;35(1):6-15. Available from: http://www.guttmacher.org/pubs/psrh/full/3500603.pdf. [pmid: 12602752].
Jones RK, Kooistra K. Abortion incidence and access to services in the United States, 2008. Perspect Sex Reprod Health. 2011;43(1):41-50. Available from: http://www.guttmacher.org/pubs/journals/4304111.pdf. [pmid: 21388504].

#### For More Information

Contact The Guttmacher Institute, 125 Maiden Lane, 7th floor, New York, NY 10038; or see The Guttmacher Institute website at: http://www.guttmacher.org.

### Organisation for Economic Cooperation and Development (OECD) Health Data

OECD provides annual data on statistical indicators for health and health systems collected from 34 member countries, with some time series going back to 1960. The international comparability of health expenditure estimates depends on the quality of national health accounts in OECD member countries. In recent years, an increasing number of countries have adopted the standards for health accounting defined by OECD, greatly increasing the comparability of national health expenditure data reporting. Additional limitations in international comparisons include differing boundaries between health care and other social care, particularly for the disabled and elderly, and underestimation of private expenditures on health.

OECD was established in 1961 with a mandate to promote policies to achieve the highest sustainable economic growth and a rising standard of living among member countries. The organization now comprises 34 member countries: Australia, Austria, Belgium, Canada, Chile, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Mexico, the Netherlands, New Zealand, Norway, Poland, Portugal, Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Turkey, the United Kingdom, and the United States.

As part of its mission, OECD has developed a number of activities related to health and health care systems. The main aim of OECD work on health policy is to conduct cross-national studies of the performance of OECD health systems and to facilitate exchanges between member countries regarding their experiences in financing, delivering, and managing health services. To support this work, each year OECD compiles cross-country data in the OECD Health Data database, one of the most comprehensive sources of comparable health-related statistics. OECD Health Data is an essential tool for conducting comparative analyses and drawing lessons from international comparisons of diverse health care systems. This international database now incorporates the first results arising from implementation of the OECD manual, A System of Health Accounts, which provides a standard framework for producing a set of comprehensive, consistent, and internationally comparable data on health spending. OECD collaborates with other international organizations such as the World Health Organization.

#### For More Information

Contact the OECD Washington Center, 2001 L Street, NW, Suite 650, Washington, DC 20036; or see the OECD website at: http://www.oecd.org/health.