# Appendixes

Appendix I Data Sources

Appendix II Definitions and Methods

Appendix III Additional Data Years Available