# Prevention

## Statin Drug Use

The percentage of adults 45 years of age and over using statin drugs has increased from 2% in 1988–1994 to 25% in 2005–2008.

High cholesterol is a risk factor for heart disease (Figure 3). Although cholesterol levels may be reduced by dietary modifications and increased physical activity, these lifestyle changes are often difficult to maintain or not sufficiently effective (1). In those cases, or for persons with other risk factors for heart disease, the use of cholesterol-lowering medications is often suggested.

Widespread belief in the value of drug therapy to lower cholesterol—and consequently to reduce mortality from heart disease—began with the introduction of statin drugs in 1987 and published studies that proved their effectiveness (2,3). There are several classes of cholesterol-lowering drugs (3,4), but statins have become the drug class of choice because of their demonstrated efficacy and safety (3,5).

From 1988–1994 to 2005–2008, the use of statin drugs by adults 45 years of age and over increased 10-fold, from 2% to 25%. There was a concurrent decline in the percentage of Americans with high serum total cholesterol (greater than or equal to 240 mg/dL) over this time period, which may be attributable to increased use of cholesterol-lowering medications, especially statins (6) (Figure 16 and Table 68).

Both men and women are increasingly taking statin drugs. However, in 2005–2008 one-half of men 65–74 years of age took a statin drug in the past 30 days, compared with just over one-third of women in that age group.

Figure 17 Statin drug use in the past 30 days among adults 45 years of age and over, by sex and age: United States, 1988–1994, 1999–2002, and 2005–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig17.ppt)

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE greater than 30%.

NOTE: See data table for Figure 17.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 17 consists of two bar charts, one for men and one for women, showing statin drug use in the past 30 days among adults 45 years of age and over, by age groups, for 1988 through 1994, 1999 through 2002, and 2005 through 2008.

### References

1 (2001). National Cholesterol Education Program. Third Report of the Expert Panel on Detection, Evaluation, and Treatment of the High Blood Cholesterol in Adults (Adult Treatment Panel III): Executive Summary.
2 Knopp RH. (1999). Drug treatment of lipid disorders. N Eng J Med.
3 Steinberg D, Gotto AM. (1999). Preventing coronary artery disease by lowering cholesterol levels: Fifty years from bench to bedside. JAMA.
4 LaRosa JC. (1995). Unresolved issues in early trials of cholesterol lowering. Am J Cardiol.
5 Evans M, Roberts A, Davies S, Rees A. (2004). Medical lipid-regulating therapy: Current evidence, ongoing trials, and future developments. Drugs.
6 Carroll MD, Lacher DA, Sorlie PD, Cleeman JI, Gordon DJ, Wolz M, et al. (2005). Trends in serum lipids and lipoproteins of adults, 1960–2002. JAMA.

## Influenza Vaccination

Between 1999 and 2009, influenza vaccination increased among adults 50–64 years of age and those 85 years and over.

Vaccination of persons at risk for complications from influenza is an important public health strategy for preventing morbidity and mortality in the United States. Thousands of deaths each year are associated with influenza (1).

In April 2000, the Advisory Committee on Immunization Practices (ACIP) recommended that all adults 50 years of age and over receive an annual influenza vaccination (2). In response to the unexpected shortfall in the 2000–2001 and 2004– 2005 influenza vaccine supply, ACIP and CDC modified the universal recommendation and established vaccine priority groups. These groups included persons 65 years of age and over and children and adults with chronic underlying health conditions (3,4). In February 2010, ACIP voted to expand the influenza recommendation for the 2010–2011 season to include all persons 6 months of age and over (5).

Between 1999 and 2009, influenza vaccination in the past 12 months among noninstitutionalized adults increased among adults 50–64 years of age and among those 85 years and over and was stable among other age groups. Among those under age 85, a decrease in coverage in 2005 was related to the influenza vaccine shortage (6).

Receipt of influenza vaccination increased with age. In 2009, 77% of adults 85 years of age and over reported an influenza vaccination in the past 12 months—nearly twice the level of those 50–64 years (41%) and four times the level of those 18–49 years (23%).

Figure 18 Influenza vaccination in the past 12 months among adults 18 years of age and over, by age: United States, 1999–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig18.ppt)

NOTE: See data table for Figure 18.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 18 is a line graph showing the trend in influenza vaccination in the past 12 months among adults 18 years of age and over, by age groups, for 1999 through 2009.

### References

1 CDC. (2010). Estimates of deaths associated with seasonal influenza—United States, 1976–2007. MMWR.
2 CDC. (2007). Prevention and control of influenza: Recommendations of the Advisory Committee on Immunization Practices (ACIP), 2007. MMWR.
3 CDC. (2000). Notice to readers: Delayed supply of influenza vaccine and adjunct ACIP influenza vaccine recommendations for the 2000–01 influenza season. MMWR.
4 CDC. (2004). Interim influenza vaccination recommendations 2004–05 influenza season. MMWR.
5 CDC.
6 CDC. (2004). Experiences with obtaining influenza vaccination among persons in priority groups during a vaccine shortage—United States, October–November, 2004. MMWR.