# Morbidity

## Health Conditions Among Children

Between 1997–1999 and 2007–2009, the percentage of children with reported food or skin allergies and with attention deficit hyperactivity disorder (ADHD or ADD) increased, while the percentage with a recent asthma attack was unchanged.

Most children enjoy good health, with only 2% of children having their health status reported as fair or poor (Table 56). Yet, this is a period when concerns about growth and development emerge and access to diagnostic and treatment services from professionals in health care, mental health, and the school system is critical. Both chronic health and developmental conditions have important consequences for children’s ability to participate in school (1).

Between 1997–1999 and 2007–2009, the percentage of children with respondent-reported food allergies increased from 3% to 5%, and the percentage with skin allergies increased from 7% to 11%. The prevalence of reported skin allergies among children was twice as high as that of food allergies. Children with food allergies were more likely to have asthma and other allergies (2).

During this period, 5% of children were reported to have had an asthma attack in the past year. Asthma attacks were more common among boys than girls and among non-Hispanic black children than among non-Hispanic white children (3) (Table 46).

The percentage of school-age children with ADHD or ADD increased from 7% to 9% during this period. School-age boys (12%) were twice as likely as girls (6%) to have ever been diagnosed with ADHD or ADD (4) (Table 46). In 2005–2008, 5% of boys 5–17 years of age and 3% of girls in that age group had recently used prescription central nervous system stimulants; these drugs are commonly prescribed for ADHD or ADD (5).

Figure 2 Respondent-reported selected conditions among children under 18 years of age: United States, 1997–1999 and 2007–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig02.ppt)

NOTES: ADHD is attention deficit hyperactivity disorder. See data table for Figure 2.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 2 is a bar chart showing respondent-reported selected conditions among children under 18 years of age, for 1997 through 1999 and 2007 through 2009.

### References

1 Van Cleave J, Gortmaker SL, Perrin JM. (2010). Dynamics of obesity and chronic health conditions among children and youth. JAMA.
2 Branum AM, Lukacs SL. (2008). Food allergy among U.S. children: Trends in prevalence and hospitalizations. NCHS data brief no 10.
3 Akinbami LJ. (2006). The state of childhood asthma, United States, 1980–2005. Advance data from vital and health statistics.
4 Pastor PN, Reuben CA. (2008). Diagnosed attention deficit hyperactivity disorder and learning disability: United States, 2004–2006. NCHS. Vital health stat.
5 CDC/NCHS. National Health and Nutrition Examination Survey.

## Heart Disease Prevalence

From 1999 to 2009, heart disease prevalence rates have remained stable among adult women in all age groups and among adult men younger than 75 years of age.

Heart disease is the leading cause of death in the United States. In 2007, one-quarter of all deaths (616,000) were from diseases of the heart (Figure 24). The majority (81%) of heart disease deaths were among people 65 years of age and over (1).

Risk factors for heart disease include obesity, lack of regular physical activity, and smoking (2–4). Over the past 40 years, smoking rates have declined and obesity rates have increased (Tables 60 and 71). Physical activity rates increased only modestly over the last decade (Figure 12). High serum total cholesterol and uncontrolled high blood pressure rates—also risk factors for cardiovascular disease—have declined among older men and women (Tables 67 and 68). The prevalence of diabetes has increased since 1988–1994 (Table 50). Among heart disease patients, medical care and preventive drug treatments have contributed to continued decreases in death rates.

Between 1999 and 2009, the prevalence of lifetime respondent-reported heart disease differed by sex and age. The proportion of adults 18–64 years of age who reported ever being diagnosed with heart disease was similar for men and women. Among older adults 65 years of age and over, respondent-reported prevalence rates were higher for men than women. Among adult women in all age groups, and among men under age 75, prevalence rates remained steady from 1999 to 2009. Among men 75 years of age and over, prevalence rates rose from 38% in 1999 to 46% in 2009. Although prevalence rates overall showed little change, age-adjusted death rates from heart disease declined by 28% from 1999 to 2007 (Table 30).

Figure 3 Respondent-reported lifetime heart disease prevalence among adults 18 years of age and over, by sex and age: United States, 1999–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig03.ppt)

NOTE: See data table for Figure 3.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 3 consists of two line graphs, one for men and one for women, showing respondent-reported lifetime heart disease prevalence among adults 18 years of age and over, by age groups, for 1999 through 2009.

### References

1 Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B. (2010). Deaths: Final data for 2007. National vital statistics reports.
2 Flegal KM, Graubard BI, Williamson DF, Gail MH. (2007). Cause-specific excess deaths associated with underweight, overweight, and obesity. JAMA.
3 CDC. (2004). The health consequences of smoking: A report of the Surgeon General.
4 U.S. Department of Health and Human Services, Office of Disease Prevention and Health Promotion (ODPHP) pub no U0036. 2008 Physical activity guidelines for Americans [online] 2008.

## Cancer Prevalence

Cancer prevalence rates increased among women 45 years of age and over and among men 75 years of age and over from 1999 to 2009.

Cancer (also called malignant neoplasm) is the second leading cause of death in the United States after heart disease. In 2007, there were 560,000 deaths from all sites of cancer combined, accounting for 23% of all deaths (Figure 24). Seven in ten (69%) cancer deaths were to persons 65 years of age and over. Cancer is the leading cause of death for persons ages 45–64 and the second leading cause of death for 25–44 year olds (1) (Table 27 and Figures 29 and 30).

Between 1999 and 2009, the percentage of adults 18 years of age and over who reported ever having been told they had cancer (excluding nonmelanoma skin cancers) increased from 5% to 6% (data table for Figure 4). This increase in lifetime prevalence was largely driven by increases in cancer prevalence among men 75 years of age and over and among women 45 years of age and over.

In 2009, lifetime cancer prevalence increased with age, from 1% to 2% among men and women 18–44 years of age to 17% to 23% among men and women 75 years of age and over. Among adults under 65 years of age, lifetime cancer prevalence rates were higher for women than men; rates were lower for older women than men. Cancer prevalence was three times as high among women 18–44 years of age as men in that age group and nearly twice as high among women 45–64 years of age as men in that age group.

Figure 4 Respondent-reported lifetime cancer prevalence among adults 18 years of age and over, by sex and age: United States, 1999–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig04.ppt)

NOTE: See data table for Figure 4.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 4 consists of two line graphs, one for men and one for women, showing respondent-reported lifetime cancer prevalence among adults 18 years of age and over, by age groups, for 1999 through 2009.

### Reference

1 Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B. (2010). Deaths: Final data for 2007. National vital statistics reports.

## Diabetes Prevalence

Diabetes prevalence among adults 20 years of age and over was 11% in 2005–2008, up from 8% in 1988–1994.

Long-term complications of diabetes include cardiovascular disease, renal failure, nerve damage, and retinal damage (1,2). Treatment guidelines for diabetes recommend dietary modifications, physical activity, weight loss (if overweight), and the possible use of medication (2,3).

Among adults 20 years of age and over, the prevalence of diabetes (including physician-diagnosed and undiagnosed diabetes) has increased from 8% in 1988–1994 to 11% in 2005–2008 (see data table for Figure 5 for definition of diabetes). The increase in diabetes prevalence was due primarily to an increase in physician-diagnosed diabetes (Table 50). The prevalence of undiagnosed diabetes has held steady from 1988–1994 to 2005–2008 at 3%.

Diabetes prevalence increases with age. In 2005– 2008, 4% of adults 20–44 years, 14% of those 45–64 years, and 27% of those 65 years of age and over had diabetes. Diabetes is more common among non-Hispanic black adults (20%) and Mexican-origin adults (17%) than among non-Hispanic white adults (9%), after age-adjusting the data (Table 50). This disparity has persisted over time.

From 1988–1994 to 2005–2008, diabetes prevalence increased among adults 20–44 years and 65 years of age and over and held steady among adults 45–64 years of age. In the past two decades, diabetes has also been reported among U.S. children and adolescents with increasing frequency. It is estimated that in 2007, almost 200,000 persons under 20 years of age had diabetes (4).

Figure 5 Diabetes prevalence among adults 20 years of age and over, by age: United States, 1988–1994 and 2005–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig05.ppt)

NOTE: See data table for Figure 5.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 5 is a bar chart showing diabetes prevalence among adults, by age groups, for 1988 through 1994 and 2005 through 2008.

### References

1 Beers MH, Fletcher AJ. (2003). Porter R, editor. Merck manual of medical information.
2 Masharani U. (2010). McPhee SJ, Papadakis MA, editors. Diabetes mellitus and hypoglycemia.
3 American Diabetes Association. (2010). Standards of medical care in diabetes—2010. Diabetes Care.
4 CDC. (2008). National diabetes fact sheet: General information and national estimates on diabetes in the United States, 2007.

## Poor Diabetes Control (Hemoglobin A1c Levels Above 9%)

The prevalence of poor diabetes control among persons diagnosed with diabetes has declined by 45% since 1988–1994 for adults 45–64 years of age and by 72% for adults 65 years of age and over.

Treatment and control of diabetes are necessary to reduce the likelihood of its complications, which include cardiovascular disease, renal failure, nerve damage, and retinal damage (1,2). Control of diabetes is generally measured by the degree of glycemic control. Good glycemic control significantly decreases retinopathy, nephropathy, and neuropathic complications. Hemoglobin A1c levels (one measure of glycemic control for persons with diabetes) help assess a patient’s average blood glucose control over several months, help indicate whether glucose control goals are being met, and evaluate whether changes in the patient’s treatment plan are needed (2). Elevated A1c values are strongly predictive of complications from diabetes. Lowering A1c values to around 7% has been shown to reduce complications; however, the target A1c value for individual patients depends on the patient’s characteristics, comorbidities, and history. In general, A1c values exceeding 9% indicate poor glycemic control (3).

From 1988–1994 to 2005–2008, the percentage of persons with diabetes who have poor glycemic control declined by 45% for adults 45–64 years of age and by 72% for older adults. There was no decline in the percentage with poor glycemic control for those 20–44 years of age. In 2005–2008, the percentage of persons with diabetes who have poor glycemic control was 26% for those 20–44 years, 14% for those 45–64 years, and 5% for those 65 years of age and over.

Figure 6 Poor diabetes control (hemoglobin A1c levels greater than 9%) among adults 20 years of age and over with diagnosed diabetes, by age: United States, 1988–1994 and 2005–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig06.ppt)

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTE: See data table for Figure 6.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 6 is a bar chart showing poor diabetes control (hemoglobin A1c levels greater than 9 percent) among adults 20 years of age and over with diagnosed diabetes, by age, for 1988 through 1994 and 2005 through 2008.

### References

1 Masharani U. (2010). McPhee SJ, Papadakis MA, editors. Diabetes mellitus and hypoglycemia.
2 American Diabetes Association. (2010). Standards of medical care in diabetes—2010. Diabetes Care.
3 Diabetes mellitus: Percent of patients with a diagnosis of diabetes mellitus having hemoglobin A1c (HbA1c) greater than 9 or not done during the past year [online].

## Joint Pain

Between 2002 and 2009, the prevalence of joint pain among adults was unchanged.

Pain affects physical and mental functioning and impacts quality of life. Pain perception and reporting are subjective and are influenced by a host of psychological and cultural factors (1). Joint pain can be caused by many types of conditions and by injury. Osteoarthritis is a common cause of joint pain (2). Factors associated with osteoarthritis include overweight, older age, and injury to a joint. Therapies that manage osteoarthritis pain and improve function include exercise, weight control, rest, over-the-counter and prescription medications, alternative therapies, and surgery (Figure 8).

Between 2002 and 2009, about 30% of adults 18 years of age and over reported recent (in the past 30 days) symptoms of pain, aching, or swelling around a joint. The knee was the most common painful joint reported (Table 53). During this period, the percentage of adults of all ages who reported recent joint pain was unchanged. Reported joint pain was strongly associated with age. In 2009, one in five adults 18–44 years, 42% of adults 45–64 years, and about one-half of adults 65–74 years and 75 years of age and over had recent joint pain. Joint pain was more common among middle-aged and older women than among men in those age categories (Table 53).

Figure 7 Joint pain in the past 30 days among adults 18 years of age and over, by age: United States, 2002–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig07.ppt)

NOTE: See data table for Figure 7.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 7 is a line graph showing joint pain in the past 30 days among adults 18 years of age and over, by age groups, for 2002 through 2009.

### References

1 NCHS. (2006). Health, United States, 2006: With chartbook on trends in the health of Americans. Special feature: Pain.
2 Osteoarthritis [online]. Medline Plus.