# Introduction

## Life Expectancy at Birth

The gap in life expectancy at birth between white persons and black persons persists but has narrowed since 1990.

Life expectancy is a measure often used to gauge the overall health of a population. As a summary measure of mortality, life expectancy represents the average number of years of life that could be expected if current death rates were to remain constant. Shifts in life expectancy are often used to describe trends in mortality. Life expectancy at birth is strongly influenced by infant and child mortality.

From 1980 through 2007, life expectancy at birth in the United States increased from 70 years to 75 years for men and from 77 years to 80 years for women (Table 22). Women have had longer life expectancy at birth in all decennial periods since 1900–1902, with white females having the longest life expectancy (1).

Racial disparities in life expectancy at birth persisted in 2007 but had narrowed since 1990. During this period, the gap in life expectancy between white males and black males narrowed from 8 years to 6 years and the gap in life expectancy between white females and black females decreased from 6 years to 4 years.

Figure 1 Life expectancy at birth, by race and sex: United States, 1980–2007

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig01.ppt)

NOTE: See data table for Figure 1.

SOURCE: CDC/NCHS, National Vital Statistics System.

Figure 1 is a line graph showing trends in life expectancy at birth, by white and black race and by sex, for 1980 through 2007.

### Reference

1 Arias E, Curtin LR, Wei R, Anderson RN. (2008). U.S. Decennial life tables for 1999–2001, United States life tables. National vital statistics reports.