# Highlights

## Special Feature on Death and Dying

In 2007, heart disease was the first leading cause of death and cancer was the second. One-quarter of all deaths were from heart disease, and 23% were from cancer, in 2007 (Figure 24).

In 2007, the infant mortality rate was 6.75 infant deaths per 1,000 live births—2% lower than in 2000 (Figure 25).

The unintentional injury death rate among children 1–14 years of age—the leading cause of death in this age group—dropped 30% from 1997 to 2007 (7 deaths per 100,000 population) (Figure 27).

Unintentional injuries accounted for nearly one-half of deaths among persons 15–24 years of age. Between 1997 and 2007, the unintentional injury death rate among this age group increased 5%, to 37 deaths per 100,000 population (Figure 28).

Between 1997 and 2007, the death rate among adults 25–44 years of age declined 7% due to a decrease in cancer and HIV-related deaths. Unintentional injuries were the leading cause of death for this age group, accounting for one-quarter of deaths in 2007 (Figure 29).

Cancer, the leading cause of death for adults 45–64 years of age, accounted for one-third of deaths among this age group in 2007. Between 1997 and 2007, the cancer death rate in this age group decreased 14%, to 200 deaths per 100,000 population (Figure 30).

Between 1997 and 2007, the heart disease death rate for adults 65 years of age and over—the leading cause of death in this age group—decreased 26%, to 1,309 deaths per 100,000 population. In 2007, heart disease accounted for 28% of deaths for adults in this age group (Figure 31).

In 2000–2007, motor-vehicle traffic death rates varied more than fourfold by state, ranging from 31 per 100,000 population in Mississippi to 7 per 100,000 population in Massachusetts (Figure 32).

On average in 2005, Medicare decedents spent 3.5 days in the ICU/CCU in the last 6 months of life. The average ranged from 5.7 days in New Jersey to 1.3 days in North Dakota (Figure 35).

One-quarter of deaths occurred at home in 2007— more than in previous years. This shift in place of death was found both for decedents under age 65 and those 65 and over. In 2007, most deaths still occurred in facilities such as hospitals (36%) and nursing homes (22%) (Figure 33).

Place of death varied by race and Hispanic origin. In 2007, among decedents 65 years of age and over, non-Hispanic white decedents were less likely to die while hospital inpatients and more likely to die in nursing homes than Hispanic, non-Hispanic black, American Indian or Alaska Native, or Asian or Pacific Islander decedents (Figure 34).

Nearly all discharged hospice care patients, 70% of current nursing home residents, and one-third of current home health care patients 65 years of age and over had advance directives in place in recent years (Figure 36).

Between 1998 and 2007, the percentage of discharged hospice care patients with a primary admission diagnosis other than cancer increased from 35% to 57% (Figure 38).

In 2007, bereavement services were offered or provided to 85% of hospice care patients’ family members or friends, and spiritual services and medication management were offered or provided to two-thirds of family members or friends. Caregiver health or wellness services were offered or provided to one-quarter of family members or friends (Figure 39).

One-half of hospice care patients had difficulty breathing, and one-third had pain at the last hospice care visit before death (Figure 40).

Ninety-one percent of hospice care patients had a narcotic analgesic (for severe pain), and 79% had an antiemetic drug (for vomiting or dizziness), prescribed for them in the last week of life (Figure 41).

## Life Expectancy

Between 2000 and 2007, life expectancy at birth increased 1.3 years for males and 1.1 years for females. The gap in life expectancy between males and females narrowed from 5.2 years in 2000 to 5.0 years in 2007 (Table 22).

Between 2000 and 2007, life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 2000, life expectancy at birth for the white population was 5.5 years longer than for the black population. By 2007, the difference had narrowed to 4.8 years (Table 22).

## Fertility and Natality

The birth rate among teenagers 15–19 years of age fell 2% in 2008 (preliminary data), to 41.5 live births per 1,000 females, reversing a brief 2-year increase that had halted the long-term decline in births to teenagers from 1991 to 2005, when rates fell 34% (Table 3).

Low birthweight is associated with elevated risk of death and disability in infants. In 2008 (preliminary data), the percentage of low birthweight births (infants weighing less than 2,500 grams (5.5 pounds) at birth) was 8.2%, unchanged from 2007. The 2008 percentage is 18% higher than for 1990 (Table 9).

## Health Risk Factors

Between 1988–1994 and 2007–2008, the prevalence of obesity among preschool-age children 2–5 years of age increased from 7% to 10% (Table 66 and Figure 13).

The prevalence of obesity among school-age children and adolescents increased between 1988–1994 and 2007–2008. The prevalence of obesity almost doubled, from 11% to 20%, among children 6–11 years of age, and increased from 11% to 18% among adolescents 12–19 years of age (Table 66 and Figure 13).

From 1988–1994 to 2007–2008, the percentage of adults 20 years of age and over who were obese increased from 22% to 34% (Table 66).

In 2009, 21% of U.S. adults were current cigarette smokers, unchanged in recent years. Men were more likely to be current cigarette smokers than women (Figure 11 and Table 58).

Between 1999 and 2009, the percentage of men and women who met the 2008 federal guidelines for aerobic activity and muscle strengthening increased for most age groups. In 2009, 19% of adults 18 years of age and over met the guidelines (Figure 12 and Table 70).

Between 1991 and 2009, the percentage of high school students who reported rarely or never using a seat belt declined from 26% to 10%. In 2009, 12% of high school boys and 8% of high school girls rarely or never used a seat belt (Table 63).

In 2009, the percentage of sexually active high school students who reported using a condom the most recent time they had sexual intercourse was 61%, up from 46% in 1991. In 2009, 69% of high school boys and 54% of high school girls used a condom at last sexual intercourse (Table 63).

## Measures of Health and Disease Prevalence

In 2007–2009, 5% of children under 18 years of age had an asthma attack in the past year, 11% had a skin allergy, and 6% had three or more ear infections in the past year. Among school-age children 5–17 years of age, 9% had attention deficit hyperactivity disorder and 6% had serious emotional or behavioral difficulties (Table 46 and Figure 2).

In 2009, the percentage of noninstitutionalized adults who reported their health as fair or poor ranged from 6% of those 18–44 years of age to 29% of those 75 years and over. The proportion of all persons with fair or poor health was five times as high among persons living in poverty as among those with family income at least four times the poverty level (Table 56).

The prevalence of hypertension (defined as high blood pressure or taking antihypertensive medication) increases with age. In 2005–2008, 33%–34% of men and women 45–54 years of age had hypertension, compared with 67% of men and 80% of women 75 years of age and over (Table 67).

In 2005–2008, 11% of adults 20 years of age and over had diabetes (diagnosed and undiagnosed). In 2005–2008, the percentage of adults with diabetes increased with age from 4% of persons 20–44 years of age to 27% of adults 65 years of age and over (Table 50 and Figure 5).

In 2009, 46% of men and 31% of women 75 years of age and over had ever been told by a physician or other health professional that they had heart disease. Among those 75 years of age and over, prevalence rose between 1999 and 2009 among men but not among women (Figure 3).

In 2009, 23% of men and 17% of women 75 years of age and over had ever been told by a physician or other health professional that they had cancer (excluding the common types of skin cancers) (Figure 4).

Between 1988–1994 and 2005–2008, the percentage of adults 20 years of age and over with high serum total cholesterol level (defined as greater than or equal to 240 mg/dL) declined from 20% to 15% (Figure 16).

In 2008–2009, 3% of the noninstitutionalized population 18 years of age and over was classified as having had serious psychological distress in a 30-day period. Adults with a family income below the poverty threshold were more than eight times as likely to report serious psychological distress as adults in families with an income at least four times the poverty level (Table 57).

## Health Care Utilization

### Use of Health Care Services

In 2008, there were about 1.2 billion visits to physician offices, hospital outpatient departments, and hospital emergency departments. There were 956 million visits to physician offices, 110 million visits to hospital outpatient departments, and 124 million visits to hospital emergency departments (Table 91).

In 2009, 21% of adults 18 years of age and over had at least one emergency department visit in the past year, and 8% had two or more visits. Emergency department utilization was 93% higher among persons with a family income below the poverty level compared with those with a family income at least four times the poverty level (Table 89).

Between 1997 and 2009, two-thirds of persons 2 years of age and over had seen a dentist in the past year. Dental visit rates were higher among children 2–17 years of age than among adults, with about three-quarters of children having had a recent dental visit during this period (Table 93).

Between 2000 and 2007, nonfederal short-stay hospital discharge rates were stable after declining sharply during the 1980s. During this period, the average length of a hospital stay was 5 days (Table 99).

The percentage of the population with at least one prescription drug during the previous month increased from 38% in 1988–1994 to 48% in 2005–2008. During the same period, the percentage taking three or more prescription drugs increased from 11% to 21% (Table 94).

### Use of Preventive Medical Care Services

In 2009, 27% of females 13–17 years of age had received three or more doses of human papillomavirus (HPV) vaccine (Table 83).

In 2009, one-half of noninstitutionalized adults 50 years of age and over had received influenza vaccination in the past year, ranging from 41% of those 50–64 years of age to 73% of those 75 years of age and over (Figure 18 and Table 84).

Between 1989 and 2009, the percentage of noninstitutionalized adults 65 years of age and over who ever received a pneumococcal vaccination quadrupled (from 14% to 61%). In 2009, 55% of those 65–74 years of age and 68% of those 75 years of age and over ever had a pneumococcal vaccination (Table 85).

The percentage of women 40 years of age and over who had a mammogram in the past 2 years more than doubled from 1987 to 1999, increasing from 29% to 70%. Between 1999 and 2008, 67%–70% of women 40 years of age and over had a mammogram within the past 2 years (Table 86).

## Unmet Need for Medical Care, Prescription Drugs, and Dental Care Due to Cost

Between 1997 and 2009, among adults 18–64 years of age, the percentage who reported not receiving, or delaying, needed medical care in the past 12 months due to cost increased from 11% to 15%; the percentage not receiving needed prescription drugs due to cost rose from 6% to 11%; and the percentage not receiving needed dental care due to cost grew from 11% to 17% (Table 76 and Figure 19).

In 2009, 37% of adults 18–64 years of age who were uninsured did not receive, or delayed, needed medical care in the past 12 months due to cost, compared with 9% of adults with private coverage and 14% of adults with Medicaid (Figure 19).

In 2009, 19%–21% of adults 18–64 years of age in families with income below 200% of poverty did not receive needed prescription drugs due to cost in the past 12 months, compared with 12% of those with a family income 200%–399% of poverty and 4% of those with a family income 400% of poverty or higher (Table 76).

In 2009, 28% of adults 18–64 years of age with any basic actions difficulty or complex activity limitation reported they did not receive needed dental care due to cost in the past 12 months, compared with 13% of adults with no disability (Table 76).

## Health Care Resources

Between 2000 and 2008, the number of physicians in patient care increased 13%, to 26 per 10,000 population. In 2008, the number of patient care physicians per 10,000 population ranged from 17 in Idaho and Mississippi to 40 in Massachusetts (Table 106).

Between 2000 and 2008, there were about 5,000 community hospitals and 800,000 community hospital beds. During that period, the community hospital occupancy rate ranged from 64% to 67% (Table 113).

In 2009, there were about 1.7 million nursing home beds in 16,000 certified nursing homes. Between 1995 and 2009, nursing home bed occupancy for the United States was relatively stable at 82%–85%. Occupancy rates were 90% or higher in 14 states and the District of Columbia in 2009 (Table 117).

The number of beds in intermediate care facilities for persons with mental retardation declined nationwide by 31% from 1995 to 2009 (Table 118).

Since their creation as part of the Balanced Budget Act of 1997, the number of critical access hospitals (small rural hospitals that are certified to receive cost-based reimbursement from Medicare) has grown to more than 1,300 in 2009. Four states (Iowa, Kansas, Minnesota, and Texas) each had more than 75 critical access hospitals in 2009 (Table 118).

## Health Care Expenditures and Payors

### Health Care Expenditures

The United States spends a larger share of its gross domestic product (GDP) on health than does any other major industrialized country. In 2007, the United States devoted 16% of its GDP to health, compared with 11% in France and 10.8% in Switzerland—the countries with the next highest shares (Table 121).

In 2008, national health care expenditures in the United States totaled $2.3 trillion, a 4.4% increase from 2007. The average per capita expenditure on health in the United States was $7,700 in 2008 (Table 122).

Expenditures for hospital care accounted for 31% of all national health expenditures in 2008. Physician and clinical services accounted for 21% of the total in 2008, prescription drugs for 10%, and nursing home care for 6% (Table 125).

Prescription drug expenditures increased 3.2% between 2007 and 2008, compared with a 4.5% increase between 2006 and 2007 (Table 125).

### Health Care Payors

In 2008, 35% of personal health care expenditures were paid by private health insurance, consumers paid 14% out of pocket, and 47% were paid by public funds. The majority of public funds went toward Medicare and Medicaid expenditures (Figure 23 and Table 126).

In 2008, the Medicare program had 45 million enrollees and expenditures of $468 billion, up from $432 billion the previous year. Expenditures for the Medicare drug program (Part D) were $49 billion in 2008, accounting for 11% of Medicare expenditures in that year (Table 140).

Of the 35 million Medicare enrollees in the fee-for-service program in 2008, 18% were under 65 years of age, compared with 12% in 1994 (Table 141).

In 2008, children under 21 years of age accounted for 48% of Medicaid recipients but only 19% of expenditures. Aged, blind, and persons with disabilities accounted for 22% of recipients and 64% of expenditures (Table 143).

In 2008, the Children’s Health Insurance Program (CHIP) accounted for less than 1% of personal health care expenditures (Table 126).

## Health Insurance Coverage

Between 2000 and 2009, the percentage of the population under 65 years of age with private health insurance obtained through the workplace declined from 67% to 58% (Table 136).

In 2009, 18% of the population under 65 years of age had no health insurance coverage (public or private) at the time of interview. Between 2000 and 2009, this percentage was 16% to 18% (Table 138).

Among the under-65 population, persons with a family income less than 400% of the poverty level were 3.1 to 5.3 times as likely to be uninsured at the time of interview as persons in higher income families in 2009 (Table 138).

In 2009, 8% of children under 18 years of age were uninsured at the time of interview. Between 2000 and 2009, among children in families with income just above the poverty level (100%–199% of poverty), the percentage uninsured dropped from 22% to 12%, whereas the percentage with coverage through Medicaid or CHIP increased from 28% to 54% (Tables 137 and 138).