# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the National Center for Health Statistics’ (NCHS) Office of Analysis and Epidemiology, under the direction of Amy B. Bernstein, Diane M. Makuc, and Linda T. Bilheimer.

Production of Health, United States, 2010, including highlights, trend tables, and appendixes, was managed by Amy B. Bernstein, Sheila Franco, and Virginia M. Freid. Trend tables were prepared by Mary Ann Bush, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila Franco, Virginia M. Freid, Tamyra C. Garcia, Ji-Eun Kim, Patricia N. Pastor, Rebecca A. Placek, Cynthia A. Reuben, and Henry Xia, with assistance from Anita L. Powell and Ilene B. Rosen. Appendix II tables and the index were assembled by Anita L. Powell. Production planning and coordination of trend tables were managed by Rebecca A. Placek. Review and clearance books were assembled by Ilene B. Rosen. Administrative and word processing assistance was provided by Lillie C. Featherstone and Danielle Wood.

Production of the Chartbook was managed by Virginia M. Freid. Data and analysis for specific charts were provided by Amy B. Bernstein, Anne K. Driscoll, Sheila Franco, Virginia M. Freid, Tamyra C. Garcia, Deborah D. Ingram, and Ji-Eun Kim. Graphs were drafted by La-Tonya D. Curl, and data tables were prepared by Rebecca A. Placek. Technical assistance and programming were provided by Mary Ann Bush, La-Tonya D. Curl, Catherine R. Duran, Xiang Liu, and Henry Xia.

Publication production was performed by the NCHS Office of Information Services, Information Design and Publishing Staff. Project management and editorial review were provided by Barbara J. Wassell. Oversight review for publications and electronic products was provided by Demarius V. Miller, Tommy C. Seibert, Jr., and Linda B. Torian. The designer was Sarah M. Hinkle. Layout and production were done by Zung T. Le and Jacqueline M. Davis. Artwork and production for Health, United States, 2010: In Brief were provided by Sarah M. Hinkle and Kyung M. Park. Printing was managed by Patricia L. Wilson, CDC/OCOO/MASO.

Electronic access through the NCHS Internet site was provided by Christine J. Brown, Jacqueline M. Davis, Zung T. Le, Anthony Lipphardt, Anita L. Powell, Sharon L. Ramirez, Ilene B. Rosen, and Barbara J. Wassell.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Vladislav Beresovsky, Frederic H. Decker, Carol J. DeFrances, Lisa L. Dwyer, Marni J. Hall, Lauren Harris-Kojetin, Maria F. Owings, Susan M. Schappert, and Ingrid Vassanelli; Division of Health Examination Statistics: Vicki L. Burt, Margaret D. Carroll, Bruce A. Dye, Mark Eberhardt, Jaime J. Gahche, Quiping Gu, Clifford L. Johnson, David A. Lacher, Cynthia L. Ogden, Susan E. Schober, Jacqueline D. Wright, and Sarah Yoon; Division of Health Interview Statistics: Patricia F. Adams, Patricia Barnes, Veronica E. Benson, Barbara Bloom, Robin A. Cohen, Susan S. Jack, John Pleis, Charlotte A. Schoenborn, and Brian W. Ward; Division of Vital Statistics: Joyce C. Abma, Robert N. Anderson, Elizabeth Arias, Anjani Chandra, Brady Hamilton, Donna L. Hoyert, Kenneth D. Kochanek, Joyce A. Martin, T. J. Mathews, Sherry L. Murphy, Michelle Osterman, and Stephanie J. Ventura; Office of Analysis and Epidemiology: Lara Akinbami, Barbara Altman, Li-Hui Chen, Deborah D. Ingram, Ellen A. Kramarow, Mitch Loeb, Susan Lukacs, Andrea P. MacKay, Laura A. Pratt, Cheryl V. Rose, Rashmi Tandon, Margaret Warner, and Julie Dawson Weeks; Office of the Center Director: Patricia Markovich and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): Epidemiology Program Office: Samuel L. Groseclose, Patsy A. Hall, and Michael Wodajo; National Center for Chronic Disease Prevention and Health Promotion: Sonya Gamble and Steve Kinchen; National Center for HIV, Viral Hepatitis, STD, and TB Prevention: Michael Campsmith, Delicia Carey, Rachel S. Wynn, Annemarie Wasley, and Jill Wasserman; National Center for Immunization and Respiratory Diseases: Christina Dorell, Gary Euler, and James A. Singleton; National Institute for Occupational Safety and Health: Roger Rosa; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: David Kashihara and Steven R. Machlin; Centers for Medicare & Medicaid Services: Dovid Chaifetz, Cathy A. Cowan, Karen Edrington, Denise Franz, Christopher Kessler, Deborah W. Kidd, Maggie S. Murgolo, Olivia Nuccio, Joseph S. Regan, Loan Swisher, and Lekha Whittle; National Institutes of Health: Kathy Cronin, Brenda Edwards, Paul W. Eggars, and Marsha Lopez; Substance Abuse and Mental Health Services Administration: Jeffrey Buck, James Colliver, Laura Milazzo-Sayre, and Rita Vandivort-Warren; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor; Bureau of Labor Statistics: Daniel Ginsburg, George Long, Stephen Pegula, Elizabeth Rogers, Swati Patel, and Peter Horner; Department of Veterans Affairs: Pheakdey Lim and Dat Tran; American Association of Colleges of Pharmacy: Jennifer M. Patton and Danielle Taylor; American Association of Colleges of Osteopathic Medicine: Wendy Fernando and Tom Levitan; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Osteopathic Association: Mark Dvorak and Margaret Harrison; American Dental Education Association: Jon D. Ruesch; Association of American Medical Colleges: Franc Slapar and Amber Sterling; Association of Schools and Colleges of Optometry: Ginny Pickles and Joanne Zuckerman; Association of Schools of Public Health: Kristin Dolinski; Cowles Research Group: C. McKeen Cowles; The Guttmacher Institute: Rachel Jones; The Dartmouth Institute for Health Policy and Clinical Practice: Kristen K. Bronner; NOVA Research Company: Shilpa Bengeri; and Thomson Reuters: Rosanna Coffey and Katharine Levit.