# Health Risk Factors

## Cigarette Smoking

Since 2004, little progress has been made in lowering the percentage of high school students and adults who smoke cigarettes.

Smoking is associated with an increased risk of heart disease, stroke, lung and other types of cancer, and chronic lung diseases (1). Smoking during pregnancy is an important preventable cause of poor pregnancy outcomes (1). Tobacco use, primarily cigarette smoking, remains the single largest preventable cause of death in the United States (2). Each year, an estimated 443,000 people die prematurely from smoking or exposure to secondhand smoke, and another 8.6 million have a serious illness caused by smoking (2). Decreasing cigarette smoking is a major public health objective. Preventing smoking among teenagers and young adults is critical because smoking usually begins in adolescence (3).

Between 1999 and 2009, cigarette smoking among males and females in grades 9–12 decreased from 35% to 19%–20%. Males and females in these grades were equally likely to smoke cigarettes in 2009.

The percentage of adults 18 years of age and over who smoked cigarettes declined between 1999 and 2004 and then stabilized at about 21%. Cigarette smoking decreased the most for younger men and women 18–44 years of age. Men under 65 years of age were more likely to smoke cigarettes than women of a similar age.

Figure 11 Cigarette smoking among students in grades 9–12 and adults 18 years of age and over, by sex, grade, and age: United States, 1999–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig11.ppt)

NOTE: See data table for Figure 11.

SOURCE: CDC/NCHS, National Health Interview Survey and CDC, Youth Risk Behavior Survey.

Figure 11 consists of two line graphs, one for males and one for females, showing cigarette smoking among students in grades 9 through 12 and among adults 18 years of age and over, by age group, for 1999 through 2009.

### References

1 CDC. (2004). The health consequences of smoking: A report of the Surgeon General.
2 Tobacco use: Targeting the Nation’s leading killer—At a glance 2010 [online].
3 CDC. (1994). Preventing tobacco use among young people: A report of the Surgeon General.

## Participation in Leisure-time Aerobic and Muscle-strengthening Activities

Between 1999 and 2009, the percentage of men and women who met the 2008 federal guidelines for aerobic activity and muscle-strengthening increased among middle-age and older age groups, but the overall level remained below 20%.

Physical activity has been shown to have significant positive health effects, including lowering the risk of chronic illness (heart disease, stroke, type 2 diabetes, high blood pressure, and certain cancers), preventing falls, avoiding weight gain, and reducing depression (1). Since 1995, the Dietary Guidelines for Americans (2) have included advice on physical activity. In 2008, the Department of Health and Human Services released updated guidelines for aerobic activity and muscle-strengthening activities for Americans (1).

Between 1999 and 2009, the percentage of men 18 years of age and over who met the 2008 federal aerobic activity and muscle-strengthening guidelines increased from 19% to 22%. Among men, the percentage who met the guidelines for those 45–64 years and 65 years of age and over increased during this period, although their levels were lower than among younger men. In 2009, 12% of men 65 years of age and over met the guidelines, compared with 28% of men 18–44 years of age.

Throughout this period, women were generally less likely to meet the guidelines than men in the same age group. The percentage of women 18 years of age and over who met the guidelines increased during this period, from 12% to 16%. As with men, the percentage who met the guidelines increased during this period for women 45–64 years and 65 years of age and over. The percentage of women who met the guidelines decreased with age (9% of women 65 years of age and over compared with 19% of women 18–44 years in 2009).

Figure 12 Participation in leisure-time aerobic and muscle-strengthening activities that meet the 2008 federal physical activity guidelines for adults 18 years of age and over, by sex and age: United States, 1999–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig12.ppt)

NOTE: See data table for Figure 12.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 12 consists of two line graphs, one for men and one for women, showing participation in leisure-time aerobic and muscle-strengthening activities that meet the 2008 federal physical activity guidelines for adults 18 years of age and over, by age group, for 1999 through 2009.

### References

1 (2008). Physical activity guidelines for Americans [online].
2 (1995). Nutrition and your health: Dietary guidelines for Americans.

## Obesity Among Children

The percentage of children who were obese rose in the 1980s and 1990s and has plateaued since then; in 2007–2008, almost one in five children older than 5 years of age was obese.

Excess body weight in children is associated with excess morbidity in childhood and adulthood (1). Obesity among children and teens 2–19 years of age is defined as a body mass index (BMI) for age and sex at or above the 95th percentile of the CDC growth charts (2). Obese children are more likely than their normal weight counterparts to become obese adults (3,4). Evidence suggests that the morbidity associated with obesity may increase with longer duration of obesity (5,6). Therefore, obesity trends among children may portend higher morbidity and mortality rates among future adults. Diet, physical inactivity, genetic factors, environment, and health conditions contribute to overweight and obesity. Changes in children’s physical activity and eating habits over time appear to contribute to increases in prevalence of obesity (7–9).

Between 1988–1994 and 1999–2000, the percentage of obese children increased in all age groups. Young children (2–5 years of age) are less likely to be obese than older children. The percentage of young children who were obese rose from 7% in 1988–1994 to 10% in 1999–2000 and has held steady since that time (10). The prevalence of obesity among 6–11 year olds increased from 11% in 1988–1994 to 15% in 1999–2000 and has not increased significantly since then. The increase was similar among adolescents (12–19 years of age) for whom the prevalence of obesity rose from 11% to 15% between 1988–1994 and 1999–2000 before leveling off during the 2000s.

Figure 13 Obesity among children, by age: United States, 1988–1994 through 2007–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig13.ppt)

NOTE: See data table for Figure 13.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 13 is a line graph showing trends in obesity among children, by age groups, for 1988 through 1994 and 2007 through 2008.

### References

1 Dietz WH. (1998). Health consequences of obesity in youth: Childhood predictors of adult disease. Pediatrics.
2 Ogden CL, Flegal KM. (2010). Changes in terminology for childhood overweight and obesity. National health statistics reports.
3 Singh AS, Mulder C, Twisk JW, van Mechelen W, Chinapaw MJ. (2008). Tracking of childhood overweight into adulthood: A systematic review of the literature. Obes Rev.
4 Freedman DS, Mei Z, Srinivasan SR, Berenson GS, Dieta WH. (2007). Cardiovascular risk factors and excess adiposity among overweight children and adolescents: The Bogalusa Heart Study. J Pediatr.
5 Gregg EW, Cheng YJ, Cadwell BL, Imperatore G, Williams DE, Flegal KM, et al. (2005). Secular trends in cardiovascular disease risk factors according to body mass index in U.S. adults. JAMA.
6 Flegal KM, Graubard BI, Williamson DF, Gail MH. (2007). Cause-specific excess deaths associated with underweight, overweight, and obesity. JAMA.
7 Danner FW. (2008). A national longitudinal study of the association between hours of TV viewing and the trajectory of BMI growth among U.S. children. J Pediatr Psychol.
8 Gortmaker SL, Must A, Sobol AM, Peterson K, Colditz GA, Dietz WH. (1996). Television viewing as a cause of increasing obesity among children in the United States, 1986–1990. Arch Pediatr Adolesc Med.
9 McMurray RG, Harrell JS, Deng S, Bradley CB, Cox LM, Bangdiwala SI. (2000). The influence of physical activity, socioeconomic status, and ethnicity on the weight status of adolescents. Obes Res.
10 Ogden CL, Carroll MD, Curtin LR, Lamb MM, Flegal KM. (2010). Prevalence of high body mass index in U.S. children and adolescents, 2007–2008. JAMA.

## Overweight and Obesity Among Adults

The proportion of American adults 20 years of age and over who were obese rose in the 1980s and 1990s. In 2007–2008, about one-third of adults were obese and about two-thirds were overweight or obese.

Excess body weight is associated with excess morbidity and mortality (1,2). Obesity (body mass index (BMI) of 30.0 or higher) is correlated with excess mortality; Grade 2+ obesity (BMI of 35.0 or higher), in particular, significantly increases the risk of death (3). Obesity is also associated with increased risk of heart disease, stroke, some cancers, diabetes, osteoarthritis, and disability (1,2,4–7). Diet, physical inactivity, genetic factors, environment, and health conditions contribute to overweight and obesity.

The proportion of men who are obese grew from 19% in 1988–1994 to 32% in 2007–2008 although there was no increase after 2005–2006. For women, this proportion increased from 25% to 35% during this period; obesity rates did not rise between 1999–2000 and 2007–2008. The proportion of men with Grade 2+ obesity doubled from 5% to 11%; the proportion of women in this category grew from 11% to 18%. In 2007–2008, 4% of men and 7% of women had a BMI of 40 or higher (Grade 3 obesity) (8). The proportion of adults who were overweight but not obese (BMI between 25 and 29.9) remained stable between 1988–1994 and 2007–2008.

Obesity patterns vary by race and ethnicity. Among women, non-Hispanic black women had the highest obesity rates, followed by Mexican-origin women (Table 71). There was less racial and ethnic variation in obesity among men.

Figure 14 Overweight and obesity among adults 20 years of age and over, by sex: United States, 1988–1994 through 2007–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig14.ppt)

NOTE: See data table for Figure 14.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 14 consists of two area graphs, one for men and one for women, showing overweight and grade 1 and grade 2 plus obesity among adults 20 years of age and over, for 1988 through 1994 and 2007 through 2008.

### References

1 National Heart, Lung, and Blood Institute and National Institute of Diabetes and Digestive and Kidney Diseases. (1998). Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: The evidence report.
2 National Task Force on the Prevention and Treatment of Obesity. (2000). Overweight, obesity, and health risk. Arch Intern Med.
3 Flegal KM, Graubard BI, Williamson DF, Gail MH. (2005). Excess deaths associated with underweight, overweight, and obesity. JAMA.
4 Ogden CL, Yanovski SZ, Carroll MD, Flegal KM. (2007). The epidemiology of obesity. Gastroenterology.
5 Gregg EW, Guralnik JM. (2007). Is disability obesity’s price of longevity?. JAMA.
6 Alley DE, Chang VW. (2007). The changing relationship of obesity and disability, 1988–2004. JAMA.
7 World Cancer Research Fund/American Institute for Cancer Research (AICR). (2007). Food, nutrition, physical activity, and the prevention of cancer: A global perspective.
8 Flegal KM, Carroll MD, Ogden CL, Curtin LR. (2010). Prevalence and trends in obesity among US adults, 1999–2008. JAMA.

## Hypertension Prevalence

Hypertension prevalence increased among all age groups for men and women 45 years of age and over.

Hypertension increases the risk for cardiovascular disease, heart attack, and stroke (1). Treatment of hypertension may include lifestyle modifications such as weight loss and a modified diet, as well as medication. Between 1988–1994 and 2005–2008, the prevalence of hypertension (defined in this figure as having an average systolic blood pressure reading of at least 140 mmHg or an average diastolic reading of at least 90 mmHg or taking antihypertensive medication) among adults 20 years of age and over increased from 24% to 32%.

During this period, the prevalence of hypertension was stable among men and women 20–44 years of age. Hypertension prevalence increased among men and women 45–64 years, 65–74 years, and 75 years of age and over. The largest increases were among women 45–64 and 65–74 years of age. Hypertension was more common among men than women 20–44 years of age, was similar among those 45–74 years, and was more common among women than men 75 years and over.

The prevalence of hypertension was higher among non-Hispanic black adults 20 years of age and over than among non-Hispanic white and Mexican-origin adults, even after age-adjusting the data (2) (Table 67). This racial disparity has persisted over time.

Between 1988–1994 and 2005–2008, the overall prevalence of uncontrolled high blood pressure (average systolic pressure of at least 140 mmHg or diastolic pressure of at least 90 mmHg among those previously told they had hypertension) among adults 20 years of age and over decreased from 74% to 54% (Table 67). The use of antihypertensive medications increased during this period (Table 95).

Figure 15 Hypertension among adults 20 years of age and over, by sex and age: United States, 1988–1994, 1999–2002, and 2005–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig15.ppt)

NOTE: See data table for Figure 15.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 15 consists of two line graphs, one for men and one for women, showing hypertension among adults 20 years of age and over, by age group, for 1988 through 1994, 1999 through 2002, and 2005 through 2008.

### References

1 (2004). National High Blood Pressure Education Program. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: Complete report.
2 CDC/NCHS. National Health and Nutrition Examination Survey [unpublished analysis].

## High Serum Total Cholesterol (240 mg/dL or Higher)

Between 1988–1994 and 2005–2008, the percentage of the population 45 years of age and over with high serum total cholesterol levels (240 mg/dL or higher) declined among all age groups of men and women.

High serum (blood) total cholesterol is a major risk factor for heart disease—the leading cause of death in the United States (1,2). Cholesterol levels may be reduced by dietary modifications and increased physical activity. Additionally, cholesterol-lowering medication may be recommended (2).

The percentage of adults 20 years of age and over with a high serum total cholesterol level (defined as measured serum total cholesterol of 240 mg/dL or higher) decreased from 20% in 1988–1994 to 15% in 2005–2008. During this period, about 10% of men and women 20–44 years of age had high serum total cholesterol. The percentage of men and women with high serum total cholesterol levels declined among those 45–64 years, 65–74 years, and 75 years of age and over. These declines may be a result of improved awareness and increased use of cholesterol-lowering medications (3) (Figure 17).

In 2005–2008, women 65–74 years and 75 years of age and over were more than twice as likely as men in those age groups to have high serum total cholesterol and were less likely to use cholesterol-lowering medications (Figure 17). The higher serum total cholesterol levels among older women may also be due to hormonal changes after menopause and because women often have higher levels of high-density lipoprotein (HDL), a component of total cholesterol (3,4).

Figure 16 High serum total cholesterol (240 mg/dL or higher) among adults 20 years of age and over, by sex and age: United States, 1988–1994, 1999–2002, and 2005–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig16.ppt)

NOTE: See data table for Figure 16.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 16 consists of two line graphs, one for men and one for women, showing high serum total cholesterol (240 milligrams per deciliter or higher) among adults 20 years of age and over, by age group, for 1988 through 1994, 1999 through 2002, and 2005 through 2008.

### References

1 American Heart Association. (2010). Heart disease and stroke statistics—2010 update. Circulation.
2 (2001). National Cholesterol Education Program. Third Report of the Expert Panel on Detection, Evaluation, and Treatment of the High Blood Cholesterol in Adults (Adult Treatment Panel III): Executive Summary.
3 Schober SE, Carroll MD, Lacher DA, Hirsch R. (2007). High serum total cholesterol—An indicator for monitoring cholesterol lowering efforts: U.S. adults, 2005–2006. NCHS data brief no 2.
4 Carroll MD, Lacher DA, Sorlie PD, Cleeman JI, Gordon DJ, Wolz M, et al. (2005). Trends in serum lipids and lipoproteins of adults, 1960–2002. JAMA.