# Health Care Utilization

## Selected Back and Joint Procedures

Between 1996–1997 and 2006–2007, total knee replacement rates increased among adults 45 years of age and over.

Knee, back, and hip pain are common conditions among middle-aged and older persons (Table 53 and Figure 7). Methods to alleviate joint and low back pain include the use of over-the-counter and prescription medications, weight loss if needed, exercise, physical therapy, and surgical procedures (1,2). Total knee replacement is one of the most commonly performed orthopedic procedures and has been shown to improve functional status and relieve the pain often associated with osteoarthritis (3). Total hip replacement procedures are commonly performed to relieve pain from osteoarthritis, whereas partial hip replacements are generally performed to repair hip fractures (4). The evidence is mixed on the efficacy of disc removal and spinal fusion to relieve back pain (5).

Between 1996–1997 and 2006–2007, inpatient procedure rates among persons 45–64 years of age doubled for total knee replacements (from 12 to 26 per 10,000 population) and increased 80%, from 7 to 12 per 10,000 population, for total hip replacements. During this period, inpatient procedure rates for excision of intervertebral disc and spinal fusion, which are typically not performed on an outpatient basis, were unchanged among this age group.

Among persons 65 years of age and over, excision of intervertebral disc and spinal fusion procedure rates increased 67%, from 17 to 28 per 10,000 population, and total knee replacement procedures increased 60%, from 51 to 82 per 10,000 population, during this period.

Figure 8 Selected back and joint procedures among adults 45 years of age and over, by age: United States, 1996–1997 through 2006–2007

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig08.ppt)

NOTE: See data table for Figure 8.

SOURCE: CDC/NCHS, National Hospital Discharge Survey.

Figure 8 consists of two line graphs showing selected back and joint procedures among adults 45 through 64 years of age and 65 years of age and over, for 1996 through 1997 and 2006 through 2007.

### References

1 Osteoarthritis [online]. Medline Plus.
2 Joint disorders [online]. Medline Plus.
3 Kane RL, Saleh KJ, Wilt TJ, Bershadsky B, Cross WW, MacDonald RM, Rutks I. (2003). Total knee replacement. Evidence report/technology assessment no 86. AHRQ pub no 04–E006–1.
4 Zhan C, Kaczmarek R, Loyo-Berrios N, Sangl J, Bright RA. (2007). Incidence and short-term outcomes of primary and revision hip replacement in the United States. J Bone Joint Surg Am.
5 Deyo RA, Nachemson A, Mirza SK. (2004). Spinal-fusion surgery—The case for restraint. N Engl J Med.

## Colorectal Tests and Procedures

Between 2000 and 2008, reported colorectal tests and procedures increased for adults 50–75 years of age among all racial and ethnic groups.

Colorectal cancer is the third most common cancer (excluding skin cancers) diagnosed in both men and women in the United States, accounting for an estimated 143,000 new cases in 2010 (1). Modifiable risk factors include a diet high in red meat, obesity, smoking, physical inactivity, and heavy alcohol consumption (1). Since 1990, age-adjusted colon cancer death rates have declined 31% overall but at a slower rate among black persons (Table 24). Declining colon cancer death rates were primarily associated with increased screening (2). Black persons have higher incidence and poorer survival for colon cancer than other racial groups (Tables 47 and 48).

In 1995, the U.S. Preventive Services Task Force first recommended screening for colorectal cancer for all persons age 50 and over (3). These recommendations were further refined in 2002 and again in 2008 (4). The task force now strongly urges adults 50–75 years of age to undergo high-sensitivity fecal occult blood testing (FOBT) annually, sigmoidoscopy every 5 years accompanied by FOBT every 3 years, or colonoscopy every 10 years.

Between 2000 and 2008, the percentage of adults 50–75 years of age who reported having colorectal procedures increased 55%, from 33% to 51% (see data table for Figure 9 for definition of colorectal procedures). Increases were noted among all racial and ethnic groups. However, Hispanic adults were less likely than adults in other racial and ethnic groups to have had colorectal procedures in 2008. Between 2000 and 2008, growth in reported colorectal procedures was fueled mainly by increased colonoscopy procedures (5).

Figure 9 Respondent-reported colorectal tests and procedures among adults 50–75 years of age, by race and Hispanic origin: United States, 2000–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig09.ppt)

NOTE: See data table for Figure 9.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 9 is a line graph showing respondent-reported colorectal tests and procedures among adults 50 through 75 years of age, by race and Hispanic origin, for 2000 through 2008.

### References

1 Cancer facts and figures, 2010 [online].
2 Edwards BK, Ward E, Kohler BA, Eheman C, Zauber AG, Anderson RN, et al. (2010). Commentary. Annual report to the Nation on the status of cancer, 1975–2006, featuring colorectal cancer trends and impact of interventions (risk factors, screening, and treatment) to reduce future rates. Cancer.
3 (1995). Guide to clinical preventive services. Report of the US Preventive Services Task Force Ch 8, Screening for colorectal cancer.
4 Screening for colorectal cancer: Topic page [online] US Preventive Services Task Force, Agency for Healthcare Research and Quality 2008Available from: http://www.uspreventiveservicestaskforce.org/uspstf/uspscolo.htm
5 CDC/NCHS. National Health Interview Survey [unpublished analysis].

## Antidepressant and Antianxiety Prescription Drug Use

Between 1988–1994 and 2005–2008, the percentage of adults taking prescription antidepressants increased almost fivefold to 11%, while the percentage taking antianxiety medications increased from 4% to 6%.

In their lifetimes, about one-half of Americans will have a serious mental health condition (1). Almost 30% of Americans will experience an anxiety disorder, and 17% will have a major depressive disorder (1). Research suggests that fewer than one-half of people with serious mental illness receive treatment (2–5). For many with mental illness, drugs are a helpful treatment option.

In addition to their use to treat depression, antidepressants are used to treat eating, anxiety, and posttraumatic stress disorders. Antianxiety medications are used for anxiety disorders and sedation. Drugs in these classes are also sometimes prescribed for subsyndromal mental health conditions and a variety of physical disorders (6,7).

From 1988–1994 to 2005–2008, the use of antidepressants increased almost fivefold among adults 18 years of age and over. In 2005–2008, 11% of adults reported taking a prescription antidepressant in the past month. Women were more than twice as likely as men to take antidepressants (16% compared with 6%). Use was higher for women 45–64 years of age, compared with younger and older women.

Use of antianxiety drugs grew by about 50% from 1988–1994 to 2005–2008. In 2005–2008, 6% of adults 18 years of age and over reported taking a prescription antianxiety drug in the past month. Women 65 years of age and over were 66% more likely to report taking antianxiety drugs than men in the same age group (12% compared with 7%). The use of antianxiety drugs is higher for those 45 years of age and over, compared with younger adults.

Figure 10 Adults 18 years of age and over reporting prescription antidepressant and antianxiety drug use in the past month, by age and sex: United States, 1988–1994 and 2005–2008

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig10.ppt)

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTE: See data table for Figure 10.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Figure 10 consists of two bar charts showing adults 18 years of age and over reporting prescription antidepressant and antianxiety drug use in the past month, by age and sex, for 1988 through 1994 and 2005 through 2008.

### References

1 Kessler RC, Berglund P, Demler O, Jin R, Merikangas KR, Walters EE. (2005). Lifetime prevalence and age-of-onset distributions of DSM–IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry.
2 Kessler RC, Berglund PA, Bruce ML, Koch JR, Laska EM, Leaf PJ, et al. (2001). The prevalence and correlates of untreated serious mental illness. Health Serv Res.
3 Colman I, Wadsworth ME, Croudace TJ, Jones PB. (2006). Three decades of antidepressant, anxiolytic and hypnotic use in a national population birth cohort. Br J Psychiatry.
4 Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. (2005). Prevalence, severity, and comorbidity of 12-month DSM–IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry.
5 Timonen M, Liukkonen T. (2008). Management of depression in adults. BMJ.
6 Stone KJ, Viera AJ, Parman CL. (2003). Off-label applications for SSRIs. Am Fam Physician.
7 Chouinard G. (2006). The search for new off-label indications for antidepressant, antianxiety, antipsychotic and anticonvulsant drugs. J Psychiatry Neurosci.