# Data Tables for Figures 1–41

## Introduction

Data table for Figure 1 Life expectancy at birth, by race and sex: United States, 1980–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig01.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig01.ppt)

Year | All races | | | Male | | Female
Year | Both sexes | Male | Female | White | Black | White | Black
| Life expectancy in years
1980 | 73.7 | 70.0 | 77.4 | 70.7 | 63.8 | 78.1 | 72.5
1990 | 75.4 | 71.8 | 78.8 | 72.7 | 64.5 | 79.4 | 73.6
1997 | 76.5 | 73.6 | 79.4 | 74.3 | 67.2 | 79.9 | 74.7
1998 | 76.7 | 73.8 | 79.5 | 74.5 | 67.6 | 80.0 | 74.8
1999 | 76.7 | 73.9 | 79.4 | 74.6 | 67.8 | 79.9 | 74.7
2000 | 76.8 | 74.1 | 79.3 | 74.7 | 68.2 | 79.9 | 75.1
2001 | 76.9 | 74.2 | 79.4 | 74.8 | 68.4 | 79.9 | 75.2
2002 | 76.9 | 74.3 | 79.5 | 74.9 | 68.6 | 79.9 | 75.4
2003 | 77.1 | 74.5 | 79.6 | 75.0 | 68.8 | 80.0 | 75.6
2004 | 77.5 | 74.9 | 79.9 | 75.4 | 69.3 | 80.4 | 76.0
2005 | 77.4 | 74.9 | 79.9 | 75.4 | 69.3 | 80.4 | 76.1
2006 | 77.7 | 75.1 | 80.2 | 75.7 | 69.7 | 80.6 | 76.5
2007 | 77.9 | 75.4 | 80.4 | 75.9 | 70.0 | 80.8 | 76.8

NOTES: Populations for computing life expectancy are 1990-based postcensal estimates of U.S. resident population for 1991–1999 and 2000-based postcensal estimates for 2001–2007. See Appendix I, Population Census and Population Estimates. Life table values for 2000 and later years were computed using a slight modification of the new life table method due to a change in the age detail of populations received from the U.S. Census Bureau. Values for data years 2000–2007 are based on a newly revised methodology that uses vital statistics death rates for ages under 66 years and modeled probabilities of death for ages 66–100 years based on blended vital statistics and Medicare probabilities of dying and may differ from figures previously published. The revised methodology is similar to that developed for the 1999–2001 decennial life tables. Starting with 2003 data, some states allowed the reporting of more than one race on the death certificate. The multiple-race data for these states were bridged to the single-race categories of the 1977 Office of Management and Budget Standards, for comparability with other states. See Appendix II, Race; Table 22.

SOURCE: CDC/NCHS, National Vital Statistics System. Arias E, Rostron BL, Tejada-Vera B. United States life tables, 2005. National vital statistics reports; vol 58 no 10. Hyattsville, MD: NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_10.pdf. Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B. Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

## Morbidity

Data table for Figure 2 Respondent-reported selected conditions among children under 18 years of age: United States, 1997–1999 and 2007–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig02.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig02.ppt)

Condition | 1997–1999 | | 2007–2009
Condition | Percent | SE | Percent | SE
Skin allergy | 7.4 | 0.2 | 10.7 | 0.3
Food allergy | 3.4 | 0.1 | 4.6 | 0.2
Asthma attack | 5.4 | 0.1 | 5.4 | 0.2
ADHD or ADD (ever diagnosed, 5–17 years of age) | 6.5 | 0.2 | 9.0 | 0.3

SE is standard error.

Notes: ADHD is attention deficit hyperactivity disorder, and ADD is attention deficit disorder; based on the parent’s or knowledgable household adult’s report of having ever been told by a doctor or other health professional that the child has ADHD or ADD. Food allergy includes digestive allergy; skin allergy includes eczema. Food allergy is based on asking “During the past 12 months has your child had any kind of food or digestive allergy?” Skin allergy is based on asking “During the past 12 months has your child had eczema or any kind of skin allergy?” Asthma attack is based on the parent’s or knowledgable household adult’s report of having ever been told by a doctor or other health professional that [child] had asthma and that [child] had an episode of asthma or an asthma attack in the past 12 months. Also see Table 46.

SOURCE: CDC/NCHS, National Health Interview Survey, sample child questionnaire.

Data table for Figure 3 Respondent-reported lifetime heart disease prevalence among adults 18 years of age and over, by sex and age: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig03.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig03.ppt)

Sex and age | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
Total
18 years and over, age-adjusted | 11.0 | 11.1 | 11.7 | 11.2 | 11.1 | 11.5 | 11.6 | 10.8 | 11.1 | 11.5 | 11.4
18 years and over, crude | 10.8 | 11.0 | 11.6 | 11.1 | 11.1 | 11.5 | 11.8 | 11.0 | 11.2 | 11.8 | 11.8
Men
18 years and over, age-adjusted | 11.9 | 11.9 | 12.6 | 12.2 | 12.1 | 12.4 | 12.5 | 12.0 | 12.4 | 12.5 | 13.1
18 years and over, crude | 11.0 | 11.0 | 11.7 | 11.4 | 11.4 | 11.7 | 12.0 | 11.4 | 11.9 | 12.1 | 12.9
18–44 years | 3.6 | 3.5 | 3.6 | 3.6 | 3.2 | 3.9 | 3.5 | 3.0 | 3.5 | 4.2 | 4.5
45–64 years | 14.1 | 13.5 | 14.1 | 13.7 | 13.7 | 13.1 | 14.9 | 13.5 | 13.0 | 13.0 | 14.5
65–74 years | 30.4 | 30.4 | 32.2 | 31.4 | 32.9 | 33.3 | 32.2 | 30.9 | 34.3 | 29.6 | 31.2
75 years and over | 37.8 | 40.5 | 44.5 | 42.3 | 42.0 | 43.0 | 41.1 | 44.9 | 45.4 | 47.3 | 45.8
Women
18 years and over, age-adjusted | 10.4 | 10.6 | 11.2 | 10.4 | 10.4 | 10.8 | 11.1 | 10.0 | 10.1 | 10.9 | 10.1
18 years and over, crude | 10.6 | 10.9 | 11.5 | 10.8 | 10.8 | 11.3 | 11.6 | 10.5 | 10.7 | 11.6 | 10.8
18–44 years | 5.2 | 4.7 | 5.5 | 4.3 | 4.4 | 5.0 | 5.1 | 4.3 | 4.8 | 5.0 | 4.3
45–64 years | 11.2 | 11.7 | 12.2 | 11.8 | 11.6 | 11.6 | 12.4 | 11.1 | 11.3 | 11.5 | 11.7
65–74 years | 20.8 | 23.1 | 22.2 | 22.1 | 22.6 | 22.1 | 22.1 | 22.1 | 20.9 | 24.0 | 21.1
75 years and over | 30.7 | 31.4 | 32.1 | 32.8 | 32.2 | 34.0 | 33.7 | 30.7 | 29.6 | 33.7 | 30.7
Total | Standard error
18 years and over, age-adjusted | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2
18 years and over, crude | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3
Men
18 years and over, age-adjusted | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4
18 years and over, crude | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
18–44 years | 0.2 | 0.3 | 0.3 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4
45–64 years | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.7
65–74 years | 1.5 | 1.4 | 1.4 | 1.5 | 1.6 | 1.5 | 1.5 | 1.7 | 1.8 | 1.6 | 1.6
75 years and over | 1.7 | 1.7 | 1.7 | 1.8 | 1.8 | 1.8 | 1.7 | 2.1 | 2.2 | 2.2 | 2.1
Women
18 years and over, age-adjusted | 0.3 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3
18 years and over, crude | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3
18–44 years | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3
45–64 years | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.7 | 0.6 | 0.6
65–74 years | 1.0 | 1.2 | 1.1 | 1.1 | 1.1 | 1.2 | 1.1 | 1.6 | 1.4 | 1.4 | 1.2
75 years and over | 1.3 | 1.2 | 1.2 | 1.3 | 1.2 | 1.2 | 1.2 | 1.4 | 1.3 | 1.3 | 1.4

NOTES: Data are for the civilian noninstitutionalized population. Heart disease prevalence is ascertained by a “yes” answer to at least one of the following four questions: “Have you EVER been told by a doctor or other health professional that you had coronary heart disease?” “Have you EVER been told by a doctor or other health professional that you had angina, also called angina pectoris?” “Have you EVER been told by a doctor or other health professional that you had a heart attack (also called myocardial infarction)?” “Have you EVER been told by a doctor or other health professional that you had any kind of heart condition or heart disease (other than the ones I asked about)?” Estimates are age-adjusted to the year 2000 standard population using five age groups: 18–44 years, 45–54 years, 55–64 years, 65–74 years, and 75 years and over. See Appendix II, Age adjustment; Table 49.

SOURCE: CDC/NCHS, National Health Interview Survey, sample adult questionnaire.

Data table for Figure 4 Respondent-reported lifetime cancer prevalence among adults 18 years of age and over, by sex and age: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig04.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig04.ppt)

Sex and age | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
Total
18 years and over, age-adjusted | 5.2 | 4.9 | 5.3 | 5.3 | 5.1 | 5.4 | 5.7 | 5.6 | 5.4 | 5.9 | 5.8
18 years and over, crude | 5.1 | 4.8 | 5.2 | 5.2 | 5.1 | 5.4 | 5.7 | 5.7 | 5.5 | 6.1 | 6.1
Men
18 years and over, age-adjusted | 4.0 | 4.1 | 4.8 | 4.6 | 4.5 | 4.9 | 5.2 | 4.9 | 4.9 | 4.7 | 5.3
18 years and over, crude | 4.2 | 3.6 | 4.3 | 4.1 | 4.1 | 4.4 | 4.7 | 4.5 | 4.6 | 4.5 | 5.1
18–44 years | 1.0 | 0.7 | 0.8 | 0.6 | 0.6 | 0.7 | 0.8 | 0.8 | 0.9 | *0.8 | *0.7
45–64 years | 4.1 | 3.0 | 3.9 | 4.0 | 4.5 | 4.1 | 4.5 | 4.2 | 4.6 | 4.5 | 4.8
65–74 years | 15.7 | 12.2 | 15.8 | 16.4 | 13.5 | 15.0 | 16.5 | 14.6 | 15.3 | 13.3 | 18.9
75 years and over | 19.0 | 21.5 | 21.7 | 19.9 | 19.7 | 24.5 | 24.2 | 24.4 | 22.0 | 21.8 | 22.7
Women
18 years and over, age-adjusted | 5.8 | 5.8 | 5.9 | 6.0 | 5.7 | 6.0 | 6.4 | 6.4 | 5.9 | 7.1 | 6.5
18 years and over, crude | 5.8 | 5.9 | 6.0 | 6.2 | 6.0 | 6.3 | 6.6 | 6.7 | 6.3 | 7.6 | 7.0
18–44 years | 2.4 | 2.5 | 2.7 | 2.7 | 2.1 | 2.5 | 2.8 | 3.0 | 2.2 | 2.8 | 2.2
45–64 years | 7.1 | 6.6 | 7.5 | 7.1 | 7.1 | 7.4 | 7.5 | 7.6 | 7.3 | 8.7 | 8.7
65–74 years | 12.3 | 12.7 | 11.9 | 12.4 | 13.9 | 13.0 | 14.1 | 12.5 | 15.3 | 15.8 | 15.3
75 years and over | 15.5 | 16.6 | 14.3 | 16.8 | 15.6 | 16.2 | 17.4 | 17.8 | 16.9 | 20.1 | 16.9
| Standard error
Total
18 years and over, age-adjusted | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.2 | 0.2 | 0.2 | 0.2
18 years and over, crude | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.2 | 0.2 | 0.2 | 0.2
Men
18 years and over, age-adjusted | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2
18 years and over, crude | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.2 | 0.2 | 0.2
18–44 years | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.1 | 0.2 | *0.2 | *0.1
45–64 years | 0.4 | 0.3 | 0.3 | 0.3 | 0.4 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
65–74 years | 1.1 | 1.0 | 1.1 | 1.3 | 1.1 | 1.1 | 1.1 | 1.4 | 1.2 | 1.2 | 1.3
75 years and over | 1.5 | 1.5 | 1.5 | 1.4 | 1.5 | 1.5 | 1.4 | 1.8 | 1.8 | 1.9 | 1.6
Women
18 years and over, age-adjusted | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2
18 years and over, crude | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.2 | 0.3 | 0.3
18–44 years | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.2 | 0.3 | 0.2
45–64 years | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.5
65–74 years | 0.9 | 0.8 | 0.8 | 0.9 | 0.9 | 0.9 | 1.0 | 1.4 | 1.0 | 1.3 | 1.1
75 years and over | 1.0 | 1.0 | 0.9 | 1.0 | 0.9 | 1.0 | 1.0 | 1.2 | 1.2 | 1.3 | 1.3

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: Data are for the civilian noninstitutionalized population. Cancer prevalence is ascertained by a “yes” answer to the question: “Have you EVER been told by a doctor or other health professional that you had a cancer or malignancy of any kind?” Excludes nonmelanoma skin carcinomas. Estimates are age-adjusted to the year 2000 standard population using five age groups: 18–44 years, 45–54 years, 55–64 years, 65–74 years, and 75 years and over. See Appendix II, Age adjustment; Table 49.

SOURCE: CDC/NCHS, National Health Interview Survey, sample adult questionnaire.

Data table for Figure 5 Diabetes prevalence among adults 20 years of age and over, by age: United States, 1988–1994 and 2005–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig05.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig05.ppt)

Age | 1988–1994 | | 2005–2008
Age | Percent | SE | Percent | SE
20 years and over, age-adjusted | 9.1 | 0.4 | 10.9 | 0.5
20 years and over, crude | 8.4 | 0.3 | 11.3 | 0.6
20–44 years | 2.6 | 0.3 | 3.7 | 0.4
45–64 years | 13.9 | 0.8 | 13.7 | 1.2
65 years and over | 19.6 | 1.0 | 26.9 | 1.5

SE is standard error.

NOTES: Diabetes prevalence estimates include physician-diagnosed and undiagnosed diabetes. Physician-diagnosed diabetes was defined by respondents answering “yes” to the question, “Have you ever been told by a doctor or health professional that you have diabetes or sugar diabetes?” and excludes women who reported having diabetes only during pregnancy. Undiagnosed diabetes is defined as a fasting blood glucose (FBG) of at least 126 mg/dL and/or a hemoglobin A1c of at least 6.5% and no reported physician diagnosis. Respondents had fasted for at least 8 hours and less than 24 hours. The definition of undiagnosed diabetes in previous editions of Health, United States did not consider hemoglobin A1c. See Appendix II, Diabetes. In 2005–2006 and 2007–2008, FBG and hemoglobin A1c testing were performed at different laboratories and using different instruments than testing in earlier years. As a result, the National Health and Nutrition Examination Survey recommended that 2005–2008 data be adjusted to be compatible with earlier years. Diabetes estimates in Health, United States were produced after adjusting the 2005–2008 laboratory data as recommended. For more information, see: http://www.cdc.gov/nchs/nhanes/nhanes2007-2008/GLU_E.htm. Estimates are age-adjusted to the year 2000 standard population using three age groups: 20–44 years, 45–64 years, and 65 years and over. See Appendix II, Age adjustment; Table 50.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 6 Poor diabetes control (hemoglobin A1c levels greater than 9%) among adults 20 years of age and over with diagnosed diabetes, by age: United States, 1988–1994 and 2005–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig06.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig06.ppt)

Age | 1988–1994 | | 2005–2008
Age | Percent | SE | Percent | SE
20 years and over, crude | 23.3 | 1.9 | 12.7 | 1.3
20–44 years | 29.5 | 5.7 | 26.3 | 4.4
45–64 years | 26.0 | 3.4 | 14.4 | 1.9
65 years and over | 18.0 | 2.5 | *5.0 | 1.0

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: Poorly controlled diabetes is defined as hemoglobin A1c (glycohemoglobin) laboratory values greater than 9%, among adults with diagnosed diabetes (based on self-report). In 2005–2006 and 2007–2008, hemoglobin A1c testing was performed at different laboratories and using different instruments than testing in earlier years. As a result, the National Health and Nutrition Examination Survey recommended that 2005–2008 data be adjusted to be compatible with earlier years. Poorly controlled diabetes estimates in Health, United States were produced after adjusting the 2005–2008 laboratory data as recommended. For more information, see: http://www.cdc.gov/nchs/nhanes/nhanes2007-2008/GHB_E.htm.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 7 Joint pain in the past 30 days among adults 18 years of age and over, by age: United States, 2002–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig07.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig07.ppt)

Age | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
18 years and over, age-adjusted | 29.5 | 31.6 | 30.8 | 30.7 | 29.2 | 27.0 | 30.5 | 32.0
18 years and over, crude | 29.5 | 31.8 | 31.1 | 31.1 | 29.7 | 27.6 | 31.3 | 33.0
18–44 years | 19.3 | 20.7 | 19.2 | 19.1 | 18.0 | 16.3 | 20.3 | 20.7
45–64 years | 37.5 | 40.2 | 39.8 | 39.9 | 38.3 | 36.4 | 39.3 | 41.8
65–74 years | 46.0 | 49.3 | 49.3 | 49.3 | 47.6 | 41.6 | 46.8 | 47.9
75 years and over | 48.7 | 52.4 | 54.2 | 52.6 | 48.8 | 46.6 | 48.1 | 53.8
| Standard error
18 years and over, age-adjusted | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
18 years and over, crude | 0.3 | 0.4 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
18–44 years | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5
45–64 years | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.7
65–74 years | 1.0 | 1.1 | 1.1 | 1.0 | 1.3 | 1.2 | 1.3 | 1.1
75 years and over | 1.1 | 1.1 | 1.1 | 1.1 | 1.2 | 1.3 | 1.4 | 1.3

NOTES: Respondents were asked, “During the past 30 days, have you had any symptoms of pain, aching, or stiffness in or around a joint?” Respondents were instructed to not include the back or neck because other questions focused on those areas. To facilitate their response, respondents were shown a card illustrating the body joints. Estimates are age-adjusted to the year 2000 standard population using five age groups: 18–44 years, 45–54 years, 55–64 years, 65–74 years, and 75 years and over. See Appendix II, Age adjustment; Table 53.

SOURCE: CDC/NCHS, National Health Interview Survey, sample adult questionnaire.

## Health Care Utilization

Data table for Figure 8 Selected back and joint procedures among adults 45 years of age and over, by age: United States, 1996–1997 through 2006–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig08.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig08.ppt)

Age and type of procedure | 1996–1997 | 1998–1999 | 2000–2001 | 2002–2003 | 2004–2005 | 2006–2007
| Number per 10,000 population
45–64 years
Excision of intervertebral disc and spinal fusion | 27.0 | 28.3 | 25.8 | 27.1 | 27.1 | 27.2
Total knee replacement | 11.9 | 13.2 | 13.9 | 20.2 | 24.5 | 25.9
Total hip replacement | 6.5 | 8.5 | 8.2 | 10.4 | 11.3 | 11.7
Partial hip replacement | 1.3 | 1.5 | 1.0 | 1.2 | 9.1 | 9.4
65 years and over
Excision of intervertebral disc and spinal fusion | 17.0 | 20.8 | 19.0 | 23.4 | 24.6 | 28.4
Total knee replacement | 51.2 | 51.4 | 58.3 | 66.8 | 82.0 | 82.1
Total hip replacement | 28.5 | 30.2 | 26.7 | 33.7 | 37.5 | 33.3
Partial hip replacement | 28.2 | 29.0 | 29.3 | 27.7 | 34.8 | 35.8
| Standard error
45–64 years
Excision of intervertebral disc and spinal fusion | 2.0 | 2.1 | 1.9 | 1.9 | 1.9 | 1.8
Total knee replacement | 0.9 | 0.9 | 1.0 | 1.6 | 2.0 | 1.8
Total hip replacement | 0.5 | 0.6 | 0.8 | 0.9 | 1.0 | 0.9
Partial hip replacement | 0.2 | 0.2 | 0.2 | 0.2 | 1.3 | 1.3
65 years and over
Excision of intervertebral disc and spinal fusion | 1.4 | 2.0 | 1.8 | 2.0 | 2.1 | 2.3
Total knee replacement | 4.2 | 3.3 | 5.0 | 4.5 | 6.6 | 5.7
Total hip replacement | 1.9 | 2.1 | 2.1 | 2.7 | 3.1 | 2.5
Partial hip replacement | 2.0 | 2.2 | 2.3 | 2.2 | 2.8 | 2.8

NOTES: Procedures are any-listed. Up to four procedures were coded for each hospital discharge. Procedure categories are based on the International Classification of Diseases, 9th Revision, Clinical Modification (ICD–9–CM). See Appendix II, Table XI for ICD–9–CM codes. Rates are based on the civilian population as of July 1. Rates for 2000 and beyond are based on the 2000 census. Rates for 1996–1999 use population estimates based on the 1990 census adjusted for net underenumeration using the 1990 National Population Adjustment Matrix from the U.S. Census Bureau. Also see Table 103.

SOURCE: CDC/NCHS, National Hospital Discharge Survey.

Data table for Figure 9 Respondent-reported colorectal tests and procedures among adults 50–75 years of age, by race and Hispanic origin: United States, selected years 2000–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig09.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig09.ppt)

Race and Hispanic origin | 2000 | | 2003 | | 2005 | | 2008
Race and Hispanic origin | Percent | SE | Percent | SE | Percent | SE | Percent | SE
Total, 50–75 years | 33.2 | 0.6 | 38.6 | 0.6 | 44.0 | 0.6 | 51.4 | 0.7
White only, not Hispanic | 35.0 | 0.7 | 40.5 | 0.7 | 47.1 | 0.7 | 54.5 | 0.8
Black only, not Hispanic | 28.8 | 1.7 | 34.8 | 1.6 | 37.7 | 1.6 | 47.2 | 2.0
Asian only | 20.2 | 3.4 | 26.5 | 3.6 | 30.1 | 3.4 | 46.2 | 3.3
Hispanic | 21.1 | 1.6 | 26.8 | 1.7 | 28.2 | 1.8 | 33.8 | 2.0

SE is standard error.

NOTES: Asian only race includes persons of Hispanic and non-Hispanic origin. Persons of Hispanic origin may be of any race. In this analysis, colorectal tests and procedures include reports of home fecal occult blood test (FOBT) in the past year, sigmoidoscopy procedure in the past 5 years with FOBT in the past 3 years, or colonoscopy in the past 10 years. Colorectal procedures are performed for diagnostic and screening purposes.

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 10 Adults 18 years of age and over reporting prescription antidepressant and antianxiety drug use in the past month, by sex and age: United States, 1988–1994 and 2005–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig10.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig10.ppt)

Sex and age | Multum Lexicon Plus therapeutic drug class
Sex and age | Antidepressant drugs | | | | Antianxiety drugs (anxiolytics, sedatives, and hypnotics)
Sex and age | 1988–1994 | | 2005–2008 | | 1988–1994 | | 2005–2008
Sex and age | Percent | SE | Percent | SE | Percent | SE | Percent | SE
Total
18 years and over, age-adjusted | 2.4 | 0.2 | 11.1 | 0.4 | 3.9 | 0.2 | 5.7 | 0.3
18 years and over, crude | 2.3 | 0.2 | 11.4 | 0.5 | 3.6 | 0.2 | 5.8 | 0.3
Men
18 years and over | 1.5 | 0.2 | 6.2 | 0.4 | 2.6 | 0.3 | 4.3 | 0.4
18–44 years | *1.0 | 0.2 | 3.6 | 0.6 | *1.0 | 0.2 | 2.1 | 0.4
45–64 years | *2.3 | 0.5 | 8.5 | 0.8 | 4.3 | 0.8 | 6.2 | 0.9
65 years and over | *2.3 | 0.5 | 10.0 | 0.9 | 6.1 | 0.9 | 7.1 | 0.9
Women
18 years and over | 3.1 | 0.3 | 16.2 | 0.7 | 4.6 | 0.3 | 7.3 | 0.5
18–44 years | 2.3 | 0.4 | 11.9 | 0.8 | 1.9 | 0.3 | 4.3 | 0.4
45–64 years | 4.6 | 0.7 | 21.9 | 1.2 | 7.5 | 0.8 | 9.3 | 0.9
65 years and over | 3.5 | 0.4 | 17.3 | 1.1 | 9.1 | 0.7 | 11.8 | 1.1

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: The drug therapeutic class is based on Lexicon Plus, a proprietary database of Cerner Multum, Inc. Lexicon Plus is a comprehensive database of all prescription and some nonprescription drug products available in the U.S. drug market. In the National Health and Nutrition Examination Survey, data on prescription drug use only are collected. Up to four classes are assigned to drugs. All four classes were included in this analysis. Drugs classified into more than one class were counted in each class. For more information, see: http://www.cdc.gov/nchs/nhanes/nhanes2007-2008/RXQ_DRUG.htm. Estimates are age-adjusted to the year 2000 standard population using three age groups: 18–44 years, 45–64 years, and 65 years and over. See Appendix II, Age adjustment; Table 94.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

## Health Risk Factors

Data table for Figure 11 Cigarette smoking among students in grades 9–12 and adults 18 years of age and over, by sex, grade, and age: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig11.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig11.ppt)

Sex, grade, and age | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
Sex and grade
Total, grades 9–12 | 34.8 | - - - | 28.5 | - - - | 21.9 | - - - | 23.0 | - - - | 20.0 | - - - | 19.5
Males, grades 9–12 | 34.7 | - - - | 29.2 | - - - | 21.8 | - - - | 22.9 | - - - | 21.3 | - - - | 19.8
Females, grades 9–12 | 34.9 | - - - | 27.7 | - - - | 21.9 | - - - | 23.0 | - - - | 18.7 | - - - | 19.1
Sex and age
Total:
18 years and over, age-adjusted | 23.3 | 23.1 | 22.6 | 22.3 | 21.5 | 20.8 | 20.8 | 20.8 | 19.7 | 20.6 | 20.6
18 years and over, crude | 23.5 | 23.2 | 22.7 | 22.4 | 21.6 | 20.9 | 20.9 | 20.8 | 19.8 | 20.6 | 20.6
Men:
18 years and over, age-adjusted | 25.2 | 25.2 | 24.6 | 24.6 | 23.7 | 23.0 | 23.4 | 23.6 | 22.0 | 22.8 | 23.2
18 years and over, crude | 25.7 | 25.6 | 25.1 | 25.1 | 24.1 | 23.4 | 23.9 | 23.9 | 22.3 | 23.1 | 23.5
18–44 years | 29.5 | 29.2 | 27.9 | 29.4 | 27.9 | 26.1 | 27.1 | 26.7 | 25.8 | 25.6 | 26.9
45–64 years | 25.8 | 26.4 | 26.4 | 24.5 | 23.9 | 25.0 | 25.2 | 24.5 | 22.6 | 24.8 | 24.5
65 years and over | 10.5 | 10.2 | 11.5 | 10.1 | 10.1 | 9.8 | 8.9 | 12.6 | 9.3 | 10.5 | 9.5
Women:
18 years and over, age-adjusted | 21.6 | 21.1 | 20.7 | 20.0 | 19.4 | 18.7 | 18.3 | 18.1 | 17.5 | 18.5 | 18.1
18 years and over, crude | 21.5 | 20.9 | 20.6 | 19.8 | 19.2 | 18.5 | 18.1 | 18.0 | 17.4 | 18.3 | 17.9
18–44 years | 25.4 | 24.5 | 24.1 | 23.0 | 22.5 | 21.4 | 21.2 | 20.6 | 19.5 | 20.6 | 20.0
45–64 years | 21.0 | 21.7 | 21.4 | 21.1 | 20.2 | 19.8 | 18.8 | 19.3 | 19.5 | 20.5 | 19.5
65 years and over | 10.7 | 9.3 | 9.1 | 8.6 | 8.3 | 8.1 | 8.3 | 8.3 | 7.6 | 8.3 | 9.5
| Standard error
Sex and grade
Total, grades 9–12 | 1.3 | - - - | 1.0 | - - - | 1.1 | - - - | 1.2 | - - - | 1.2 | - - - | 0.8
Males, grades 9–12 | 1.5 | - - - | 1.3 | - - - | 1.1 | - - - | 1.1 | - - - | 1.5 | - - - | 1.0
Females, grades 9–12 | 1.3 | - - - | 1.1 | - - - | 1.4 | - - - | 1.3 | - - - | 1.1 | - - - | 0.9
Sex and age
Total:
18 years and over, age-adjusted | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4
18 years and over, crude | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4
Men:
18 years and over, age-adjusted | 0.5 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.6 | 0.5
18 years and over, crude | 0.5 | 0.5 | 0.4 | 0.5 | 0.4 | 0.4 | 0.5 | 0.5 | 0.6 | 0.6 | 0.5
18–44 years | 0.7 | 0.6 | 0.6 | 0.7 | 0.6 | 0.6 | 0.7 | 0.8 | 0.8 | 0.8 | 0.8
45–64 years | 0.8 | 0.8 | 0.8 | 0.7 | 0.8 | 0.8 | 0.8 | 0.9 | 0.9 | 1.0 | 0.9
65 years and over | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.6 | 0.9 | 0.8 | 0.9 | 0.7
Women:
18 years and over, age-adjusted | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.4
18 years and over, crude | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.4
18–44 years | 0.6 | 0.5 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7
45–64 years | 0.7 | 0.7 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.8 | 0.8
65 years and over | 0.6 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.6 | 0.6 | 0.7

- - - Data not available.

NOTES: Data are for men and women 18 years of age and over in the civilian noninstitutionalized population. Estimates are age-adjusted to the 2000 standard population using five age groups: 18–24 years, 25–34 years, 35–44 years, 45–64 years, and 65 years and over. Age-adjusted estimates in this table may differ from other age-adjusted estimates presented elsewhere if different age groups are used in the adjustment procedure. Cigarette smoking is defined as: among men and women 18 years of age and over, those who ever smoked 100 cigarettes in their lifetime and now smoke every day or some days; among high school students in grades 9–12, those who smoked cigarettes on one or more of the 30 days preceding the survey. See Appendix II, Age adjustment; Cigarette smoking; Tables 58–60.

SOURCE: CDC/NCHS, National Health Interview Survey (data for men and women); National Center for Chronic Disease Prevention and Health Promotion, Youth Risk Behavior Survey (data for students).

Data table for Figure 12 Participation in leisure-time aerobic and muscle-strengthening activities that meet the 2008 federal physical activity guidelines for adults 18 years of age and over, by sex and age: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig12.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig12.ppt)

Sex and age | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
Total
18 years and over, age-adjusted | 15.0 | 15.0 | 16.6 | 16.8 | 17.0 | 16.2 | 16.6 | 16.2 | 16.6 | 18.4 | 19.1
18 years and over, crude | 15.2 | 15.1 | 16.6 | 16.8 | 16.9 | 16.1 | 16.5 | 16.0 | 16.5 | 18.1 | 18.8
Men
18 years and over, age-adjusted | 18.0 | 17.9 | 19.7 | 19.7 | 19.5 | 18.3 | 19.1 | 18.7 | 19.7 | 21.9 | 22.2
18 years and over, crude | 18.5 | 18.2 | 20.1 | 20.0 | 19.7 | 18.5 | 19.2 | 18.7 | 19.7 | 21.8 | 22.1
18–44 years | 23.7 | 23.0 | 26.1 | 25.6 | 24.9 | 23.6 | 24.6 | 24.1 | 25.0 | 27.3 | 27.7
45–64 years | 13.7 | 14.2 | 14.8 | 15.2 | 15.6 | 13.9 | 14.5 | 15.0 | 15.8 | 18.1 | 18.5
65 years and over | 8.1 | 8.4 | 8.4 | 9.7 | 9.8 | 9.7 | 10.0 | 8.1 | 10.2 | 11.5 | 11.8
Women
18 years and over, age-adjusted | 12.1 | 12.3 | 13.6 | 14.0 | 14.6 | 14.1 | 14.3 | 13.8 | 13.7 | 15.0 | 16.2
18 years and over, crude | 12.1 | 12.2 | 13.4 | 13.8 | 14.4 | 14.0 | 14.1 | 13.6 | 13.5 | 14.7 | 15.8
18–44 years | 15.7 | 15.0 | 17.3 | 17.2 | 17.7 | 16.5 | 16.8 | 16.6 | 15.6 | 17.4 | 19.0
45–64 years | 10.3 | 11.5 | 11.6 | 13.3 | 13.7 | 14.1 | 14.3 | 12.7 | 14.4 | 14.6 | 15.3
65 years and over | 4.2 | 5.7 | 5.4 | 5.1 | 6.0 | 6.5 | 6.4 | 7.0 | 6.1 | 8.0 | 8.6
| Standard error
Total
18 years and over, age-adjusted | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
18 years and over, crude | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
Men
18 years and over, age-adjusted | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.6 | 0.5
18 years and over, crude | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.4 | 0.4 | 0.5 | 0.5 | 0.6 | 0.5
18–44 years | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.7 | 0.9 | 0.8 | 0.9 | 0.8
45–64 years | 0.7 | 0.6 | 0.6 | 0.6 | 0.7 | 0.6 | 0.6 | 0.8 | 0.8 | 0.9 | 0.8
65 years and over | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.8 | 0.9 | 1.0 | 0.9
Women
18 years and over, age-adjusted | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.3 | 0.4 | 0.4 | 0.4 | 0.5 | 0.4
18 years and over, crude | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
18–44 years | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.7 | 0.6 | 0.7 | 0.7
45–64 years | 0.5 | 0.6 | 0.5 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.7
65 years and over | 0.4 | 0.5 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.7 | 0.6 | 0.6 | 0.7

NOTES: Starting with Health, United States, 2010, measures of physical activity changed to reflect the 2008 federal physical activity guidelines for Americans (available from: http://www.health.gov/PAGuidelines/). This new table presents the percentage of adults who fully met the 2008 federal guidelines for both aerobic activity and muscle strengthening. The 2008 federal guidelines recommend that for substantial health benefits, adults perform at least 150 minutes (2 hours and 30 minutes) a week of moderate-intensity, or 75 minutes (1 hour and 15 minutes) a week of vigorous-intensity aerobic physical activity, or an equivalent combination of moderate- and vigorous-intensity aerobic activity. Aerobic activity should be performed in episodes of at least 10 minutes, and preferably it should be spread throughout the week. The 2008 guidelines also recommend that adults perform muscle-strengthening activities that are moderate or high intensity and involve all major muscle groups on two or more days a week because these activities provide additional health benefits. See Table 70; Appendix II, Physical activity, leisure-time. Estimates are age-adjusted to the year 2000 standard population using five age groups: 18–44 years, 45–54 years, 55–64 years, 65–74 years, and 75 years and over. Age-adjusted estimates in this table may differ from other age-adjusted estimates based on the same data and presented elsewhere if different age groups are used in the adjustment procedure. See Appendix II, Age adjustment.

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 13 Obesity among children, by age: United States, 1988–1994 through 2007–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig13.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig13.ppt)

Age | 1988–1994 | 1999–2000 | 2001–2002 | 2003–2004 | 2005–2006 | 2007–2008
| Percent
2–5 years | 7.2 | 10.3 | 10.6 | 13.9 | 11.0 | 10.4
6–11 years | 11.3 | 15.1 | 16.3 | 18.8 | 15.1 | 19.6
12–19 years | 10.5 | 14.8 | 16.7 | 17.4 | 17.8 | 18.1
| Standard error
2–5 years | 0.7 | 1.7 | 1.8 | 1.6 | 1.2 | 1.3
6–11 years | 1.0 | 1.4 | 1.6 | 1.3 | 2.1 | 1.2
12–19 years | 0.9 | 0.9 | 1.1 | 1.7 | 1.8 | 1.7

NOTES: Obesity among children and youth is defined as a body mass index (BMI) at or above the sex- and age-specific 95th percentile BMI cut points from the 2000 CDC Growth Charts. Also see Table 72.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 14 Overweight and obesity among adults 20 years of age and over, by sex: United States, 1988–1994 to 2007–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig14.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig14.ppt)

Sex and obesity/overweight | 1988–1994 | 1999–2000 | 2001–2002 | 2003–2004 | 2005–2006 | 2007–2008
20 years and over, age-adjusted | Percent
Total:
Grade 2+ obesity | 8.1 | 13.2 | 12.1 | 12.2 | 14.8 | 14.3
Grade 1 obesity | 14.8 | 17.3 | 18.5 | 19.9 | 19.6 | 19.5
Overweight (not including obese) | 33.0 | 34.0 | 35.1 | 34.1 | 32.6 | 34.2
Men:
Grade 2+ obesity | 5.3 | 9.8 | 9.0 | 9.4 | 11.6 | 10.7
Grade 1 obesity | 14.9 | 17.7 | 18.8 | 21.7 | 21.8 | 21.5
Overweight (not including obese) | 40.5 | 39.7 | 42.2 | 39.7 | 39.9 | 40.0
Women:
Grade 2+ obesity | 10.7 | 16.5 | 15.0 | 15.0 | 18.0 | 17.8
Grade 1 obesity | 14.7 | 16.9 | 18.3 | 18.1 | 17.4 | 17.6
Overweight (not including obese) | 25.8 | 28.6 | 28.2 | 28.6 | 25.5 | 28.6
20 years and over, crude
Total:
Grade 2+ obesity | 8.0 | 13.1 | 12.1 | 12.3 | 15.0 | 14.3
Grade 1 obesity | 14.4 | 17.2 | 18.5 | 20.0 | 19.7 | 19.6
Overweight (not including obese) | 32.6 | 33.9 | 35.0 | 34.2 | 32.6 | 34.4
Men:
Grade 2+ obesity | 5.3 | 9.7 | 9.1 | 9.4 | 11.7 | 10.7
Grade 1 obesity | 14.3 | 17.5 | 18.7 | 21.8 | 21.8 | 21.5
Overweight (not including obese) | 39.9 | 39.4 | 42.2 | 39.7 | 39.8 | 40.1
Women:
Grade 2+ obesity | 10.5 | 16.4 | 15.0 | 15.1 | 18.1 | 17.7
Grade 1 obesity | 14.5 | 16.9 | 18.3 | 18.3 | 17.6 | 17.8
Overweight (not including obese) | 25.7 | 28.6 | 28.1 | 29.0 | 25.7 | 28.9
20 years and over, age-adjusted | Standard error
Total:
Grade 2+ obesity | 0.5 | 0.9 | 0.9 | 0.7 | 1.0 | 0.8
Grade 1 obesity | 0.4 | 0.8 | 0.8 | 0.8 | 0.7 | 0.6
Overweight (not including obese) | 0.6 | 1.0 | 1.2 | 1.1 | 0.8 | 0.8
Men:
Grade 2+ obesity | 0.5 | 1.1 | 1.2 | 0.5 | 1.0 | 0.8
Grade 1 obesity | 0.7 | 1.0 | 0.8 | 1.1 | 1.4 | 0.9
Overweight (not including obese) | 0.8 | 1.4 | 1.4 | 1.5 | 1.3 | 1.4
Women:
Grade 2+ obesity | 0.7 | 1.2 | 1.0 | 1.1 | 1.3 | 1.0
Grade 1 obesity | 0.6 | 1.0 | 1.3 | 1.3 | 0.6 | 0.8
Overweight (not including obese) | 0.7 | 1.6 | 1.7 | 1.2 | 1.2 | 1.2
20 years and over, crude
Total:
Grade 2+ obesity | 0.5 | 0.9 | 0.9 | 0.7 | 1.0 | 0.8
Grade 1 obesity | 0.4 | 0.8 | 0.8 | 0.8 | 0.7 | 0.6
Overweight (not including obese) | 0.6 | 1.0 | 1.2 | 1.1 | 0.8 | 0.7
Men:
Grade 2+ obesity | 0.5 | 1.1 | 1.3 | 0.5 | 1.1 | 0.8
Grade 1 obesity | 0.6 | 1.0 | 0.8 | 1.1 | 1.5 | 0.9
Overweight (not including obese) | 0.8 | 1.4 | 1.4 | 1.4 | 1.3 | 1.3
Women:
Grade 2+ obesity | 0.7 | 1.2 | 1.0 | 1.0 | 1.3 | 0.9
Grade 1 obesity | 0.6 | 1.0 | 1.3 | 1.3 | 0.6 | 0.8
Overweight (not including obese) | 0.7 | 1.6 | 1.7 | 1.2 | 1.3 | 1.2

NOTES: Data are for the civilian noninstitutionalized population. Overweight (not including obese) is defined as a body mass index (BMI) equal to or greater than 25 but less than 30. Grade 1 obesity is defined as a BMI equal to or greater than 30 but less then 35, and Grade 2+ obesity is defined as a BMI of 35 or greater. Pregnant women 18 years of age and over were excluded in all years. See Appendix II, Body mass index (BMI). Estimates are age-adjusted to the year 2000 standard population using three age groups: 20–39 years, 40–59 years, and 60 years and over. See Appendix II, Age adjustment; Table 71.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 15 Hypertension among adults 20 years of age and over, by sex and age: United States, 1988–1994, 1999–2002, and 2005–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig15.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig15.ppt)

Sex and age | 1988–1994 | | 1999–2002 | | 2005–2008
Sex and age | Percent | SE | Percent | SE | Percent | SE
Total
20 years and over, age-adjusted | 25.5 | 0.6 | 30.0 | 0.8 | 30.9 | 0.7
20 years and over, crude | 24.1 | 0.8 | 30.2 | 1.0 | 32.1 | 0.7
20–44 years | 8.7 | 0.6 | 10.3 | 0.8 | 11.1 | 0.7
45–64 years | 33.5 | 1.1 | 38.3 | 1.7 | 40.6 | 1.2
65–74 years | 55.4 | 1.5 | 66.8 | 1.9 | 66.5 | 1.8
75 years and over | 68.8 | 1.5 | 77.6 | 1.2 | 75.0 | 1.0
Men
20 years and over, age-adjusted | 26.4 | 0.9 | 28.8 | 1.2 | 31.6 | 0.9
20 years and over, crude | 23.8 | 1.0 | 27.6 | 1.2 | 31.4 | 0.9
20–44 years | 10.9 | 1.0 | 12.1 | 1.3 | 14.1 | 1.0
45–64 years | 34.2 | 1.6 | 36.4 | 2.0 | 40.2 | 1.6
65–74 years | 54.4 | 2.8 | 59.6 | 3.1 | 64.0 | 2.6
75 years and over | 60.4 | 2.2 | 69.0 | 1.9 | 67.2 | 2.1
Women
20 years and over, age-adjusted | 24.4 | 0.6 | 30.6 | 0.7 | 29.8 | 0.7
20 years and over, crude | 24.4 | 0.9 | 32.7 | 1.1 | 32.8 | 0.9
20–44 years | 6.5 | 0.5 | 8.3 | 0.8 | 7.9 | 0.7
45–64 years | 32.8 | 1.5 | 40.0 | 1.8 | 41.1 | 1.9
65–74 years | 56.2 | 1.7 | 72.7 | 2.2 | 68.4 | 2.4
75 years and over | 73.6 | 1.8 | 83.1 | 1.4 | 80.4 | 1.9

SE is standard error.

NOTES: Estimates are age-adjusted to the year 2000 standard population using five age groups: 20–34 years, 35–44 years, 45–64 years, 55–64 years, and 65 years and over. Hypertension is defined as having an average measured systolic blood pressure of at least 140 mmHg or an average measured diastolic of at least 90 mmHg or taking antihypertensive drugs. See Appendix II, Age adjustment; Blood pressure, high; Table 67.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 16 High serum total cholesterol (240 mg/dL or higher) among adults 20 years of age and over, by sex and age: United States, 1988–1994, 1999–2002, and 2005–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig16.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig16.ppt)

Sex and age | 1988–1994 | | 1999–2002 | | 2005–2008
Sex and age | Percent | SE | Percent | SE | Percent | SE
Total
20 years and over, age-adjusted | 20.8 | 0.6 | 17.3 | 0.6 | 14.9 | 0.6
20 years and over, crude | 19.6 | 0.6 | 17.3 | 0.7 | 15.2 | 0.6
20–44 years | 10.9 | 0.6 | 12.3 | 0.8 | 11.3 | 0.7
45–64 years | 30.4 | 1.2 | 22.6 | 1.1 | 20.3 | 1.1
65–74 years | 32.3 | 1.8 | 24.0 | 1.6 | 15.6 | 1.1
75 years and over | 31.6 | 1.7 | 20.2 | 1.2 | 14.9 | 1.6
Men
20 years and over, age-adjusted | 19.0 | 0.7 | 16.4 | 0.9 | 13.4 | 0.7
20 years and over, crude | 17.7 | 0.7 | 16.5 | 0.9 | 13.8 | 0.7
20–44 years | 12.5 | 0.7 | 14.2 | 1.0 | 12.0 | 1.0
45–64 years | 27.2 | 1.6 | 22.2 | 1.7 | 18.5 | 1.4
65–74 years | 21.9 | 2.2 | 13.7 | 1.8 | 7.9 | 1.3
75 years and over | 20.4 | 1.8 | 10.2 | 1.3 | 8.6 | 1.2
Women
20 years and over, age-adjusted | 22.0 | 0.8 | 17.8 | 0.7 | 16.0 | 0.7
20 years and over, crude | 21.3 | 0.9 | 18.0 | 0.8 | 16.6 | 0.7
20–44 years | 9.4 | 0.8 | 10.4 | 0.9 | 10.7 | 0.9
45–64 years | 33.4 | 1.6 | 23.0 | 1.5 | 22.1 | 1.5
65–74 years | 41.3 | 2.4 | 32.3 | 2.3 | 21.8 | 1.6
75 years and over | 38.2 | 2.2 | 26.5 | 1.8 | 19.4 | 2.3

SE is standard error.

NOTES: Estimates are age-adjusted to the year 2000 standard population using five age groups: 20–34 years, 35–44 years, 45–64 years, 55–64 years, and 65 years and over. See Appendix II, Cholesterol. Two measures of high cholesterol are presented in Health, United States: high serum total cholesterol (presented here) and high cholesterol, which includes both those with high serum total cholesterol and those taking medication to control their cholesterol levels. Also see Table 68 for data on the prevalence of high cholesterol.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

## Prevention

Data table for Figure 17 Statin drug use in the past 30 days among adults 45 years of age and over, by sex and age: United States, 1988–1994, 1999–2002, and 2005–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig17.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig17.ppt)

Sex and age | 1988–1994 | | 1999–2002 | | 2005–2008
Sex and age | Percent | SE | Percent | SE | Percent | SE
Total
45 years and over | 2.4 | 0.3 | 15.6 | 0.7 | 25.1 | 0.7
45–64 years | 2.2 | 0.3 | 12.2 | 1.0 | 17.2 | 0.9
65–74 years | 3.7 | 0.7 | 24.9 | 1.6 | 42.0 | 1.5
75 years and over | *1.4 | 0.4 | 18.4 | 1.2 | 41.4 | 1.3
Men
45 years and over | 2.3 | 0.3 | 17.5 | 1.1 | 26.9 | 0.9
45–64 years | 2.5 | 0.5 | 15.1 | 1.4 | 18.3 | 1.2
65–74 years | * | * | 25.7 | 1.5 | 49.7 | 2.1
75 years and over | * | * | 18.6 | 1.7 | 45.0 | 1.4
Women
45 years and over | 2.6 | 0.5 | 13.9 | 0.8 | 23.6 | 1.1
45–64 years | 1.9 | 0.5 | 9.6 | 1.0 | 16.1 | 1.2
65–74 years | *4.9 | 1.0 | 24.2 | 2.6 | 36.0 | 2.2
75 years and over | *1.7 | 0.5 | 18.2 | 1.9 | 38.9 | 2.1

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE greater than 30%.

NOTES: Respondents reporting use of a prescription drug containing any of the following ingredients—atorvastatin, cerivastatin, fluvastatin, lovastatin, pravastatin, rosuvastatin, or simvastatin—were classified as taking a statin drug. Also see Figure 16, Table 68.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 18 Influenza vaccination in the past 12 months among adults 18 years of age and over, by age: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig18.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig18.ppt)

Year | Influenza vaccination in the past 12 months
Year | 18 years and over | | | | 18–49 years | | 50–64 years | | 65–74 years | | 75–84 years | | 85 years and over
Year | Age-adjusted | | Crude | | 18–49 years | | 50–64 years | | 65–74 years | | 75–84 years | | 85 years and over
Year | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE
1999 | 28.4 | 0.3 | 27.9 | 0.3 | 16.4 | 0.3 | 34.1 | 0.7 | 61.9 | 1.0 | 70.9 | 1.2 | 68.6 | 2.1
2000 | 28.7 | 0.3 | 28.4 | 0.3 | 17.1 | 0.3 | 34.6 | 0.7 | 61.1 | 1.0 | 68.6 | 1.1 | 67.7 | 2.2
2001 | 26.7 | 0.3 | 26.4 | 0.3 | 15.0 | 0.3 | 32.2 | 0.7 | 60.7 | 1.0 | 65.7 | 1.1 | 66.4 | 2.1
2002 | 28.3 | 0.3 | 28.0 | 0.3 | 16.2 | 0.3 | 34.0 | 0.7 | 60.9 | 1.0 | 71.6 | 1.1 | 70.3 | 2.0
2003 | 29.2 | 0.3 | 29.0 | 0.3 | 16.8 | 0.3 | 36.8 | 0.7 | 60.5 | 1.0 | 72.4 | 1.1 | 66.6 | 2.1
2004 | 29.5 | 0.3 | 29.4 | 0.3 | 17.9 | 0.4 | 35.9 | 0.7 | 60.1 | 1.0 | 69.3 | 1.1 | 71.0 | 2.0
2005 | 21.6 | 0.3 | 21.4 | 0.3 | 10.7 | 0.3 | 23.0 | 0.6 | 53.7 | 1.0 | 65.3 | 1.2 | 69.9 | 1.9
2006 | 27.4 | 0.3 | 27.6 | 0.4 | 15.6 | 0.4 | 33.2 | 0.8 | 60.1 | 1.3 | 68.5 | 1.3 | 71.2 | 2.3
2007 | 29.9 | 0.4 | 30.1 | 0.4 | 17.8 | 0.4 | 36.2 | 0.9 | 61.6 | 1.2 | 71.9 | 1.3 | 74.6 | 2.4
2008 | 32.1 | 0.4 | 32.6 | 0.4 | 20.1 | 0.5 | 39.6 | 0.8 | 60.9 | 1.2 | 72.7 | 1.4 | 79.1 | 2.2
2009 | 34.1 | 0.4 | 34.7 | 0.4 | 23.0 | 0.5 | 40.7 | 0.7 | 61.5 | 1.1 | 72.0 | 1.3 | 76.5 | 1.8

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Estimates are based on the question: “During the past 12 months, have you had a flu shot? A flu shot is usually given in the fall and protects against influenza for the flu season.” Beginning in September 2003, respondents were asked about influenza vaccination by nasal spray (sometimes called by the brand name FluMist) during the past 12 months, in addition to the question regarding the flu shot. Starting with 2005 data, receipt of nasal spray or flu shot were included in the calculation of influenza vaccination estimates. Annual influenza vaccination has been recommended for all adults 50 years and over since 2000. Due to the shortfall in the 2000–2001 and 2004–2005 influenza vaccine supply, CDC recommended vaccine be reserved for priority groups, including those 65 years of age and over and those 2–64 years with chronic underlying health conditions. For more information, see: CDC. Prevention and control of influenza: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR 2000;49(RR–03):1–38. Available from: http://www.cdc.gov/mmwr/PDF/rr/rr4903.pdf. Interim influenza vaccination recommendations, 2004–05 influenza season. MMWR 2004; 53(39):923–4. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5339a6.htm.

CDC. Notice to readers: Updated recommendations from the Advisory Committee on Immunization Practices in response to delays in supply of influenza vaccine for the 2000–01 season. MMWR 2000;49(39);888–92. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm4927a4.htm. Estimates are age-adjusted to the year 2000 standard population using four age groups: 18–49 years, 50–64 years, 65–74 years, and 75 years and over. See Appendix II, Age adjustment; Table 84.

SOURCE: CDC/NCHS, National Health Interview Survey.

## Access to Care

Data table for Figure 19 Adults 18–64 years of age who delayed or did not receive needed medical care in the past 12 months due to cost, by age and type of health insurance coverage: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig19.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig19.ppt)

Age and type of insurance | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
18–64 years
Total | 9.2 | 9.2 | 9.5 | 9.7 | 10.6 | 11.4 | 11.0 | 11.7 | 11.8 | 13.6 | 15.1
Private | 5.0 | 5.0 | 5.1 | 5.1 | 5.8 | 6.2 | 5.9 | 6.4 | 6.3 | 7.8 | 8.6
Medicaid | 11.4 | 12.7 | 12.3 | 11.3 | 12.2 | 11.9 | 12.0 | 12.6 | 11.9 | 14.1 | 13.6
Uninsured | 25.8 | 24.7 | 25.5 | 26.1 | 28.1 | 30.2 | 29.5 | 29.7 | 31.4 | 33.1 | 36.5
18–44 years
Total | 9.4 | 9.5 | 9.8 | 9.9 | 10.8 | 11.4 | 11.3 | 11.7 | 12.0 | 13.6 | 15.1
Private | 5.1 | 5.0 | 5.3 | 5.1 | 5.9 | 6.2 | 5.9 | 6.2 | 6.4 | 7.6 | 8.3
Medicaid | 9.8 | 11.4 | 10.9 | 10.6 | 11.2 | 10.0 | 11.2 | 11.7 | 10.0 | 12.1 | 11.4
Uninsured | 24.3 | 23.1 | 24.1 | 24.1 | 25.5 | 27.5 | 27.1 | 26.7 | 28.9 | 30.3 | 33.6
45–64 years
Total | 8.9 | 8.8 | 8.9 | 9.4 | 10.3 | 11.2 | 10.6 | 11.7 | 11.6 | 13.5 | 15.1
Private | 4.9 | 4.9 | 4.8 | 4.9 | 5.6 | 6.2 | 5.9 | 6.6 | 6.3 | 8.1 | 9.0
Medicaid | 15.2 | 15.7 | 15.4 | 12.9 | 14.5 | 16.1 | 13.9 | 14.6 | 15.9 | 18.2 | 18.2
Uninsured | 30.8 | 29.8 | 30.2 | 32.0 | 36.1 | 38.0 | 36.2 | 38.0 | 37.9 | 40.1 | 43.7
| Standard error
18–64 years
Total | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3
Private | 0.1 | 0.1 | 0.1 | 0.1 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2
Medicaid | 0.7 | 0.7 | 0.7 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.7
Uninsured | 0.6 | 0.6 | 0.5 | 0.5 | 0.6 | 0.5 | 0.5 | 0.7 | 0.7 | 0.7 | 0.7
18–44 years
Total | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3
Private | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.2 | 0.3 | 0.3
Medicaid | 0.8 | 0.8 | 0.8 | 0.7 | 0.7 | 0.7 | 0.7 | 0.9 | 0.8 | 0.8 | 0.7
Uninsured | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.8 | 0.8 | 0.8 | 0.7
45–64 years
Total | 0.3 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3 | 0.2 | 0.3 | 0.3 | 0.4 | 0.4
Private | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3
Medicaid | 1.4 | 1.2 | 1.2 | 1.2 | 1.1 | 1.1 | 1.0 | 1.2 | 1.3 | 1.4 | 1.2
Uninsured | 1.1 | 1.0 | 1.0 | 1.1 | 1.1 | 1.0 | 0.9 | 1.4 | 1.2 | 1.1 | 1.1

NOTES: Totals include other types of insurance coverage not shown and unknown health insurance status. Based on persons responding “yes” to at least one of the following questions: “During the past 12 months was there any time when person needed medical care but did not get it because person couldn’t afford it?” or “During the past 12 months has medical care been delayed because of worry about the cost?” Health insurance categories are mutually exclusive. Persons who reported both Medicaid and private coverage are classified as having private coverage. State-sponsored health plan coverage is included as Medicaid coverage. Starting with 1999, coverage by the Children’s Health Insurance Program (CHIP) is included with Medicaid coverage. Persons not covered by private insurance, Medicaid, CHIP, state-sponsored health plans, Medicare, or military plans are considered to to have no health insurance coverage. Adults with Indian Health Service coverage only are considered to have no coverage. See Appendix II, Health insurance coverage; Tables 76 and 77.

SOURCE: CDC/NCHS, National Health Interview Survey, family core questionnaire.

Data table for Figure 20 Persons who did not receive needed dental services in the past 12 months due to cost, by sex and age: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig20.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig20.ppt)

Sex and age | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
Total | 7.9 | 8.1 | 8.7 | 8.6 | 9.2 | 10.7 | 10.7 | 10.8 | 10.5 | 12.6 | 13.3
Under 18 years | 6.5 | 6.2 | 6.7 | 5.9 | 5.6 | 6.6 | 7.3 | 6.9 | 6.3 | 7.0 | 7.1
18 years and over | 8.3 | 8.7 | 9.3 | 9.4 | 10.3 | 12.0 | 11.8 | 12.0 | 11.7 | 14.2 | 15.1
18–44 years | 10.2 | 10.7 | 11.3 | 11.5 | 12.3 | 14.5 | 14.1 | 14.2 | 14.2 | 16.6 | 18.2
45–64 years | 7.9 | 7.9 | 8.7 | 8.7 | 10.2 | 11.3 | 11.5 | 12.6 | 11.3 | 14.9 | 14.9
65 years and over | 2.7 | 3.4 | 3.5 | 4.0 | 4.0 | 5.5 | 5.2 | 3.9 | 5.0 | 5.6 | 6.2
Male | 6.9 | 6.9 | 7.3 | 7.6 | 8.1 | 9.7 | 9.3 | 9.5 | 9.2 | 11.3 | 12.0
Under 18 years | 6.4 | 5.8 | 5.8 | 5.3 | 5.4 | 7.3 | 7.3 | 6.2 | 5.5 | 7.1 | 7.5
18 years and over | 7.0 | 7.3 | 7.8 | 8.4 | 9.0 | 10.5 | 9.9 | 10.5 | 10.3 | 12.6 | 13.3
18–44 years | 8.6 | 9.1 | 9.5 | 10.3 | 10.5 | 12.6 | 11.9 | 12.0 | 12.5 | 14.7 | 15.5
45–64 years | 6.3 | 6.5 | 6.9 | 7.5 | 8.8 | 9.5 | 9.2 | 11.4 | 9.5 | 12.7 | 13.3
65 years and over | 2.3 | 2.3 | 3.2 | 3.4 | 3.7 | 4.6 | 4.3 | 3.0 | 4.3 | 5.4 | 5.8
Female | 8.8 | 9.2 | 10.0 | 9.4 | 10.3 | 11.8 | 12.1 | 12.1 | 11.8 | 13.8 | 14.5
Under 18 years | 6.7 | 6.6 | 7.7 | 6.5 | 5.9 | 5.9 | 7.2 | 7.5 | 7.2 | 6.9 | 6.6
18 years and over | 9.4 | 9.9 | 10.6 | 10.3 | 11.5 | 13.4 | 13.5 | 13.4 | 13.1 | 15.7 | 16.7
18–44 years | 11.6 | 12.3 | 13.1 | 12.7 | 14.1 | 16.4 | 16.2 | 16.4 | 15.9 | 18.5 | 20.8
45–64 years | 9.3 | 9.3 | 10.5 | 9.9 | 11.6 | 12.9 | 13.7 | 13.7 | 13.1 | 17.1 | 16.4
65 years and over | 3.0 | 4.2 | 3.8 | 4.4 | 4.1 | 6.2 | 5.8 | 4.5 | 5.4 | 5.8 | 6.5
| Standard error
Total | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3
Under 18 years | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.3 | 0.3
18 years and over | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3
18–44 years | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5
45–64 years | 0.4 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5
65 years and over | 0.2 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4
Male | 0.3 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4
Under 18 years | 0.4 | 0.4 | 0.4 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5
18 years and over | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
18–44 years | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.6 | 0.6 | 0.6 | 0.6
45–64 years | 0.5 | 0.5 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.6 | 0.5 | 0.7 | 0.7
65 years and over | 0.3 | 0.3 | 0.4 | 0.5 | 0.4 | 0.5 | 0.5 | 0.4 | 0.6 | 0.6 | 0.6
Female | 0.2 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4
Under 18 years | 0.4 | 0.4 | 0.5 | 0.4 | 0.4 | 0.4 | 0.4 | 0.6 | 0.5 | 0.5 | 0.5
18 years and over | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4
18–44 years | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.6 | 0.6 | 0.7 | 0.7
45–64 years | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.6 | 0.7 | 0.7
65 years and over | 0.3 | 0.4 | 0.3 | 0.4 | 0.4 | 0.5 | 0.5 | 0.4 | 0.5 | 0.5 | 0.5

NOTES: Data are for the civilian noninstitutionalized population. Based on persons responding “yes” to the question, “During the past 12 months was there any time when [person] needed dental care (including check-ups) but did not get it because [person] couldn’t afford it?” Also see Tables 76 and 77.

SOURCE: CDC/NCHS, National Health Interview Survey.

## Health Insurance Coverage

Data table for Figure 21 Health insurance coverage among children, by type of coverage and age: United States 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig21.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig21.ppt)

Type of coverage and age | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
Private
Under 19 years | 68.9 | 66.7 | 66.4 | 63.7 | 63.2 | 63.3 | 62.3 | 59.5 | 59.9 | 58.6 | 56.1
Under 18 years | 68.8 | 66.6 | 66.3 | 63.5 | 63.0 | 63.2 | 62.1 | 59.4 | 59.8 | 58.4 | 55.8
Medicaid
Under 19 years | 17.7 | 19.2 | 21.0 | 24.3 | 25.4 | 25.8 | 26.6 | 29.4 | 29.3 | 30.6 | 33.9
Under 18 years | 18.1 | 19.6 | 21.5 | 24.8 | 26.0 | 26.4 | 27.2 | 29.9 | 29.8 | 31.3 | 34.5
Uninsured
Under 19 years | 12.2 | 12.9 | 11.6 | 11.2 | 10.2 | 9.6 | 9.7 | 9.8 | 9.4 | 9.5 | 8.5
Under 18 years | 11.9 | 12.6 | 11.2 | 10.9 | 9.8 | 9.2 | 9.3 | 9.5 | 9.0 | 9.0 | 8.2
| Standard error
Private
Under 19 years | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.8
Under 18 years | 0.5 | 0.5 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.8
Medicaid
Under 19 years | 0.4 | 0.5 | 0.4 | 0.5 | 0.5 | 0.5 | 0.5 | 0.7 | 0.6 | 0.7 | 0.7
Under 18 years | 0.4 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.7 | 0.6 | 0.7 | 0.7
Uninsured
Under 19 years | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4
Under 18 years | 0.3 | 0.3 | 0.4 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4

NOTES: Data are for the civilian noninstitutionalized population. State-sponsored health plan coverage is included with Medicaid. Starting with 1999, coverage by the Children’s Health Insurance Program (CHIP) is included with Medicaid. Uninsured children are not covered by private insurance, Medicaid, CHIP, state-sponsored or other government-sponsored health plans, Medicare, or military plans. Children with only Indian Health Service coverage are considered to have no coverage. Percents do not add to 100 because the percentage of children with Medicare, military plans, and other government-sponsored plans is not shown and because children with both private insurance and Medicaid appear in both categories. Starting with data from the third quarter of 2004, persons under 65 years of age with no reported coverage were asked explicitly about Medicaid coverage. Estimates for Medicaid coverage shown in this table include the additional information. Estimates for 2000–2002 were calculated using 2000-based sample weights and may differ from estimates in other reports that used 1990-based sample weights for 2000–2002 estimates. See Appendix II, Health insurance coverage; Tables 135, 137, and 138.

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 22 Health insurance coverage among adults 18–64 years of age, by type of coverage and age: United States, 1999–2009

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig22.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig22.ppt)

Type of coverage and age | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009
| Percent
Private
18–44 years | 72.0 | 70.5 | 70.1 | 68.7 | 67.7 | 67.3 | 66.6 | 65.0 | 65.5 | 64.4 | 61.7
45–64 years | 79.3 | 78.7 | 78.6 | 77.3 | 77.3 | 77.1 | 76.9 | 75.2 | 75.5 | 74.3 | 72.6
Medicaid
18–44 years | 5.7 | 5.6 | 6.3 | 7.1 | 7.4 | 7.7 | 8.3 | 8.6 | 8.7 | 9.2 | 10.3
45–64 years | 4.4 | 4.5 | 4.7 | 5.3 | 5.3 | 5.5 | 5.5 | 6.3 | 5.9 | 6.4 | 6.9
Uninsured
18–44 years | 21.0 | 22.4 | 22.2 | 23.0 | 23.5 | 23.5 | 23.5 | 24.6 | 23.9 | 24.4 | 25.9
45–64 years | 12.2 | 12.6 | 12.2 | 13.1 | 12.5 | 12.8 | 12.9 | 13.2 | 13.5 | 13.6 | 14.6
| Standard error
Private
18–44 years | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.5
45–64 years | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.5
Medicaid
18–44 years | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.3 | 0.3
45–64 years | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.2
Uninsured
18–44 years | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4
45–64 years | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.3 | 0.4

NOTES: Data are for the civilian noninstitutionalized population. The category Medicaid includes state-sponsored plans and Children’s Health Insurance Program (CHIP) (starting in 1999). Uninsured adults are not covered by private insurance, Medicaid, CHIP, state-sponsored or other government-sponsored health plans, Medicare, or military plans. Adults with only Indian Health Service coverage are considered to have no coverage. Percents do not add to 100 because the percentage of adults with Medicare, military plans, and other government-sponsored plans is not shown and because adults with both private insurance and Medicaid appear in both categories. Starting with data from the third quarter of 2004, persons under 65 years of age with no reported coverage were asked explicitly about Medicaid coverage. Estimates for Medicaid coverage shown in this table include the additional information. Estimates for 2000–2002 were calculated using 2000-based sample weights and may differ from estimates in other reports that used 1990-based sample weights for 2000–2002 estimates. See Appendix II, Health insurance coverage; Tables 135, 137, and 138.

SOURCE: CDC/NCHS, National Health Interview Survey.

## Personal Health Care Expenditures

Data table for Figure 23 Personal health care expenditures, by source of funds: United States, 1998–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig23.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig23.ppt)

Source of funds | 1998 | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 1998–2008
| Amount in billions | | | | | | | | | | | AAPC
Total (PHCE) | $1,010 | $1,068 | $1,139 | $1,238 | $1,340 | $1,448 | $1,550 | $1,655 | $1,763 | $1,866 | $1,952 | 7.1
Private funds | 575 | 612 | 652 | 697 | 752 | 810 | 860 | 916 | 964 | 1,016 | 1,044 | 6.9
Out-of-pocket | 175 | 184 | 193 | 200 | 211 | 225 | 235 | 248 | 255 | 270 | 278 | 5.3
Private insurance | 344 | 371 | 403 | 441 | 482 | 522 | 560 | 600 | 635 | 665 | 691 | 8.0
Public funds | 435 | 456 | 487 | 541 | 588 | 637 | 689 | 739 | 799 | 850 | 908 | 8.5
Federal funds | 332 | 346 | 370 | 412 | 448 | 486 | 527 | 562 | 620 | 661 | 718 | 8.9
Medicare | 202 | 206 | 216 | 239 | 256 | 274 | 300 | 326 | 382 | 408 | 444 | 9.1
Medicaid (including CHIP) | 93 | 101 | 110 | 123 | 137 | 149 | 160 | 165 | 162 | 171 | 186 | 7.9
State and local funds | 103 | 109 | 117 | 130 | 140 | 151 | 162 | 177 | 179 | 189 | 190 | 7.1
Medicaid (including CHIP) | 65 | 70 | 77 | 86 | 94 | 102 | 110 | 124 | 124 | 132 | 131 | 8.2

NOTES: AAPC is average annual percent change. This rate assumes that the change is at the same rate from 1998 to 2008. PHCE is personal health care expenditures, which are outlays for goods and services relating directly to patient care. CHIP is Children’s Health Insurance Program. CHIP expenditures started in 1998. See Appendix II, Average annual rate of change (percent change); Health expenditures, national; Table 126.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Expenditure Accounts. National health expenditures, 2008. Available from: http://www.cms.hhs.gov/NationalHealthExpendData/ and unpublished data.

## Special Feature on Death and Dying

Data table for Figure 24 Deaths for all ages, by age and cause of death: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig24.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig24.ppt)

Age and cause of death | Number of deaths | Percent distribution
All ages | 2,423,712 | 100.0
Under 25 years | 73,970 | 3.1
25–44 years | 122,178 | 5.0
45–64 years | 471,796 | 19.5
65–74 years | 389,238 | 16.1
75–84 years | 652,682 | 26.9
85 years and over | 713,647 | 29.4
All causes | 2,423,712 | 100.0
Heart disease | 616,067 | 25.4
Cancer | 562,875 | 23.2
Stroke | 135,952 | 5.6
Chronic lower respiratory diseases (CLRD) | 127,924 | 5.3
Unintentional injuries | 123,706 | 5.1
Alzheimer’s disease | 74,632 | 3.1
Diabetes | 71,382 | 2.9
All other causes | 711,174 | 29.3

NOTES: Cancer refers to malignant neoplasms; stroke refers to cerebrovascular diseases; and unintentional injuries is preferred to “accidents” in the public health community. See Appendix II, Cause of death.

SOURCE: CDC/NCHS, National Vital Statistics System. Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B.

Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

Data table for Figure 25 Infant, neonatal, and postneonatal mortality rates: United States, 1997–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig25.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig25.ppt)

Year | Infant | Neonatal | Postneonatal
| Deaths per 1,000 live births
1997 | 7.23 | 4.77 | 2.45
1998 | 7.20 | 4.80 | 2.40
1999 | 7.06 | 4.73 | 2.33
2000 | 6.91 | 4.63 | 2.28
2001 | 6.85 | 4.54 | 2.31
2002 | 6.97 | 4.66 | 2.31
2003 | 6.85 | 4.62 | 2.23
2004 | 6.79 | 4.52 | 2.27
2005 | 6.87 | 4.54 | 2.34
2006 | 6.69 | 4.45 | 2.24
2007 | 6.75 | 4.41 | 2.33

Cause of infant death, 2007 | Number | Percent distribution
All causes | 29,138 | 100.0
Congenital malformations | 5,785 | 19.9
Low birthweight | 4,857 | 16.7
Sudden infant death syndrome | 2,453 | 8.4
Maternal complications | 1,769 | 6.1
Unintentional injuries | 1,285 | 4.4
All other causes | 12,989 | 44.6

NOTES: Infant is defined as under 1 year of age, neonatal as under 28 days of age, and postneonatal as 28 days through 11 months of life. See related Table 21.

SOURCE: CDC/NCHS, National Vital Statistics System: Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B.

Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

Data table for Figure 26 Death rates among children 1–19 years of age, by OECD country: 3-year average of most recent data, 2001–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig26.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig26.ppt)

OECD Country | Child mortality rate | Years (average annual)
Portugal | 34.60 | 2001–2003
United States | 32.67 | 2003–2005
New Zealand | 32.05 | 2002–2004
Slovak Republic | 30.15 | 2003–2005
Belgium | 28.97 | 1995–1997
Poland | 28.13 | 2003–2005
Hungary | 25.75 | 2003–2005
Czech Republic | 24.92 | 2003–2005
Austria | 24.57 | 2004–2006
Australia | 23.66 | 2001–2003
Finland | 23.54 | 2004–2006
Spain | 23.49 | 2003–2005
Canada | 23.43 | 2002–2004
Greece | 23.15 | 2004–2006
Denmark | 22.93 | 1999–2001
Republic of Korea | 22.36 | 2004–2006
Ireland | 21.97 | 2003–2005
Italy | 21.76 | 2001–2003
Norway | 21.49 | 2003–2005
Germany | 21.23 | 2002–2004
United Kingdom | 21.17 | 2003–2005
France | 21.04 | 2003–2005
Netherlands | 20.49 | 2002–2004
Switzerland | 20.33 | 2003–2005
Sweden | 19.27 | 2002–2004
Japan | 18.23 | 2004–2006
Iceland | 16.95 | 2003–2005
Luxembourg | 14.84 | 2003–2005

NOTES: OECD is Organisation for Economic Co-operation and Development. Child mortality rates are the number of deaths among children 1–19 years of age per 100,000 children. Data for Belgium and Denmark were the most current available.

SOURCE: World Health Organization mortality database 2008. Available from: http://stats.oecd.org/Index.aspx.

Data table for Figure 27 Death rates for leading causes of death among children 1–14 years of age: United States, 1997–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig27.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig27.ppt)

Year | All causes | Unintentional injuries | Cancer | Congenital malformations | Homicide | Heart disease
| Deaths per 100,000 population
1997 | 24.5 | 9.6 | 2.7 | 1.9 | 1.5 | 0.9
1998 | 23.4 | 9.2 | 2.5 | 1.7 | 1.5 | 1.0
1999 | 22.9 | 8.9 | 2.5 | 1.7 | 1.4 | 0.8
2000 | 22.0 | 8.5 | 2.5 | 1.6 | 1.3 | 0.8
2001 | 21.6 | 8.1 | 2.5 | 1.7 | 1.3 | 0.9
2002 | 21.2 | 7.7 | 2.6 | 1.7 | 1.4 | 0.7
2003 | 21.0 | 7.6 | 2.6 | 1.6 | 1.2 | 0.8
2004 | 20.5 | 7.6 | 2.5 | 1.7 | 1.2 | 0.8
2005 | 20.1 | 7.2 | 2.4 | 1.6 | 1.3 | 0.7
2006 | 19.0 | 6.8 | 2.3 | 1.5 | 1.3 | 0.7
2007 | 19.2 | 6.7 | 2.3 | 1.6 | 1.3 | 0.7
| Standard error
1997 | 0.21 | 0.13 | 0.07 | 0.06 | 0.05 | 0.04
1998 | 0.20 | 0.13 | 0.07 | 0.05 | 0.05 | 0.04
1999 | 0.20 | 0.13 | 0.07 | 0.06 | 0.05 | 0.04
2000 | 0.20 | 0.12 | 0.07 | 0.05 | 0.05 | 0.04
2001 | 0.20 | 0.12 | 0.07 | 0.05 | 0.05 | 0.04
2002 | 0.19 | 0.12 | 0.07 | 0.05 | 0.05 | 0.04
2003 | 0.19 | 0.12 | 0.07 | 0.05 | 0.05 | 0.04
2004 | 0.19 | 0.12 | 0.07 | 0.05 | 0.05 | 0.04
2005 | 0.19 | 0.11 | 0.07 | 0.05 | 0.05 | 0.04
2006 | 0.18 | 0.11 | 0.06 | 0.05 | 0.05 | 0.04
2007 | 0.18 | 0.11 | 0.06 | 0.05 | 0.05 | 0.04

Cause of death, 2007 | Number | Percent distribution
All causes | 10,850 | 100.0
Unintentional injuries | 3,782 | 34.8
Cancer | 1,323 | 12.2
Congenital malformations | 920 | 8.5
Homicide | 744 | 6.8
Heart disease | 414 | 3.8
All other causes | 3,667 | 33.8

NOTES: Causes of death shown are the five leading causes of death among persons 1–14 years of age in 2007. Death rates for 1997–1998 are based on International Classification of Diseases, 9th Revision. Starting in 1999, death rates are based on International Classification of Diseases, 10th Revision. Comparability ratios for selected revisions are available from: http://www.cdc.gov/nchs/nvss/mortality/comparability_icd.htm. Homicide refers to deaths due to assault. Cancer refers to malignant neoplasms. See Appendix II, Cause of death; Comparability ratio; Tables 35, 36, 38, 45, and 46.

SOURCE: CDC/NCHS, National Vital Statistics System. Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B.

Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

Data table for Figure 28 Death rates for leading causes of death among persons 15–24 years of age: United States, 1997–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig28.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig28.ppt)

Year | All causes | Unintentional injuries | Homicide | Suicide | Cancer | Heart disease
| Deaths per 100,000 population
1997 | 84.6 | 35.7 | 16.3 | 11.2 | 4.4 | 2.9
1998 | 80.6 | 35.0 | 14.3 | 10.9 | 4.5 | 2.8
1999 | 79.3 | 35.3 | 12.9 | 10.1 | 4.5 | 2.8
2000 | 79.9 | 36.0 | 12.6 | 10.2 | 4.4 | 2.6
2001 | 80.7 | 36.1 | 13.3 | 9.9 | 4.3 | 2.5
2002 | 81.4 | 38.0 | 12.9 | 9.9 | 4.3 | 2.5
2003 | 81.5 | 37.1 | 13.0 | 9.7 | 4.0 | 2.7
2004 | 80.1 | 37.0 | 12.2 | 10.3 | 4.1 | 2.5
2005 | 81.4 | 37.4 | 13.0 | 10.0 | 4.1 | 2.7
2006 | 82.2 | 38.2 | 13.5 | 9.9 | 3.9 | 2.5
2007 | 79.9 | 37.4 | 13.1 | 9.7 | 3.9 | 2.6
| Standard error
1997 | 0.48 | 0.31 | 0.21 | 0.17 | 0.11 | 0.09
1998 | 0.46 | 0.30 | 0.19 | 0.17 | 0.11 | 0.09
1999 | 0.45 | 0.30 | 0.18 | 0.16 | 0.11 | 0.08
2000 | 0.45 | 0.30 | 0.18 | 0.16 | 0.11 | 0.08
2001 | 0.45 | 0.30 | 0.18 | 0.16 | 0.10 | 0.08
2002 | 0.45 | 0.31 | 0.18 | 0.16 | 0.10 | 0.08
2003 | 0.44 | 0.30 | 0.18 | 0.15 | 0.10 | 0.08
2004 | 0.44 | 0.30 | 0.17 | 0.16 | 0.10 | 0.08
2005 | 0.44 | 0.30 | 0.18 | 0.15 | 0.10 | 0.08
2006 | 0.44 | 0.30 | 0.18 | 0.15 | 0.10 | 0.08
2007 | 0.43 | 0.30 | 0.18 | 0.15 | 0.10 | 0.08

Cause of death, 2007 | Number | Percent distribution
All causes | 33,982 | 100.0
Unintentional injuries | 15,897 | 46.8
Homicide | 5,551 | 16.3
Suicide | 4,140 | 12.2
Cancer | 1,653 | 4.9
Heart disease | 1,084 | 3.2
All other causes | 5,657 | 16.6

NOTES: Causes of death shown are the five leading causes of death among persons 15–24 years of age in 2007. Death rates for 1997–1998 are based on the International Classification of Diseases, 9th Revision. Starting in 1999, death rates are based on the International Classification of Diseases, 10th Revision. Comparability ratios for selected revisions are available from: http://www.cdc.gov/nchs/nvss/mortality/comparability_icd.htm. Homicide refers to deaths due to assault. Suicide refers to deaths from intentional self-harm. Cancer refers to malignant neoplasms. See Appendix II, Cause of death; Comparability ratio; Tables 35, 36, 38, 45, and 46.

SOURCE: CDC/NCHS, National Vital Statistics System. Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B.

Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

Data table for Figure 29 Death rates for leading causes of death among persons 25–44 years of age: United States, 1997–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig29.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig29.ppt)

Year | All causes | Unintentional injuries | Cancer | Heart disease | Suicide | Homicide | HIV
| Deaths per 100,000 population
1997 | 157.7 | 31.4 | 25.4 | 19.3 | 14.5 | 10.0 | 12.9
1998 | 153.7 | 31.5 | 25.0 | 19.6 | 14.3 | 9.2 | 10.1
1999 | 152.9 | 31.8 | 24.3 | 19.5 | 13.6 | 8.7 | 10.5
2000 | 153.2 | 32.0 | 24.0 | 19.0 | 13.4 | 8.7 | 9.8
2001 | 157.6 | 32.8 | 24.3 | 19.5 | 13.8 | 11.2 | 9.4
2002 | 156.2 | 34.5 | 23.5 | 19.9 | 14.0 | 9.1 | 8.9
2003 | 155.2 | 34.8 | 22.9 | 20.0 | 13.8 | 9.1 | 8.2
2004 | 150.0 | 35.1 | 21.8 | 19.1 | 13.9 | 8.9 | 7.5
2005 | 150.8 | 36.8 | 21.6 | 19.0 | 13.7 | 9.4 | 6.8
2006 | 149.8 | 38.6 | 20.9 | 18.6 | 13.8 | 9.2 | 6.2
2007 | 145.9 | 38.1 | 20.0 | 18.0 | 14.3 | 9.3 | 5.6
| Standard error
1997 | 0.43 | 0.19 | 0.17 | 0.15 | 0.13 | 0.11 | 0.12
1998 | 0.42 | 0.19 | 0.17 | 0.15 | 0.13 | 0.10 | 0.11
1999 | 0.42 | 0.19 | 0.17 | 0.15 | 0.13 | 0.10 | 0.11
2000 | 0.42 | 0.19 | 0.17 | 0.15 | 0.13 | 0.10 | 0.11
2001 | 0.43 | 0.20 | 0.17 | 0.15 | 0.13 | 0.12 | 0.11
2002 | 0.43 | 0.20 | 0.17 | 0.15 | 0.13 | 0.10 | 0.10
2003 | 0.43 | 0.20 | 0.16 | 0.15 | 0.13 | 0.10 | 0.10
2004 | 0.42 | 0.20 | 0.16 | 0.15 | 0.13 | 0.10 | 0.09
2005 | 0.42 | 0.21 | 0.16 | 0.15 | 0.13 | 0.11 | 0.09
2006 | 0.42 | 0.21 | 0.16 | 0.15 | 0.13 | 0.10 | 0.09
2007 | 0.42 | 0.21 | 0.15 | 0.15 | 0.13 | 0.11 | 0.08

Cause of death, 2007 | Number | Percent distribution
All cause | 122,178 | 100.0
Unintentional injuries | 31,908 | 26.1
Cancer | 16,751 | 13.7
Heart disease | 15,062 | 12.3
Suicide | 12,000 | 9.8
Homicide | 7,810 | 6.4
HIV | 4,663 | 3.8
All other causes | 33,984 | 27.8

NOTES: Causes of death shown are the six leading causes of death among persons 25–44 years of age in 2007. Death rates for 1997–1998 are based on the International Classification of Diseases, 9th Revision. Starting in 1999, death rates are based on the International Classification of Diseases, 10th Revision. Comparability ratios for selected revisions are available from: http://www.cdc.gov/nchs/nvss/mortality/comparability_icd.htm. Cancer refers to malignant neoplasms. Suicide refers to deaths from intentional self-harm. Homicide refers to deaths due to assault. HIV is human immunodeficiency virus (HIV) disease. See Appendix II, Cause of death; Comparability ratio; Tables 35, 36, 38, 45, and 46.

SOURCE: CDC/NCHS, National Vital Statistics System. Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B.

Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

Data table for Figure 30 Death rates for leading causes of death among persons 45–64 years of age: United States, 1997–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig30.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig30.ppt)

Year | All causes | Cancer | Heart disease | Unintentional injuries | Diabetes | Stroke | Chronic lower respiratory diseases (CLRD)
| Deaths per 100,000 population
1997 | 669.7 | 234.1 | 179.9 | 29.9 | 22.6 | 27.3 | 23.0
1998 | 652.8 | 228.0 | 171.9 | 30.2 | 22.5 | 26.3 | 22.3
1999 | 649.4 | 224.9 | 164.3 | 31.4 | 22.9 | 25.2 | 23.9
2000 | 647.6 | 221.2 | 159.6 | 31.9 | 22.8 | 25.8 | 22.6
2001 | 639.1 | 216.7 | 153.3 | 32.6 | 23.1 | 24.1 | 22.5
2002 | 638.4 | 214.5 | 152.7 | 34.5 | 23.3 | 23.9 | 22.1
2003 | 639.4 | 211.8 | 149.6 | 36.4 | 23.9 | 23.4 | 22.7
2004 | 625.8 | 207.2 | 143.1 | 37.6 | 23.1 | 22.8 | 21.6
2005 | 629.9 | 205.4 | 141.8 | 40.1 | 23.3 | 22.5 | 23.0
2006 | 623.0 | 202.7 | 138.3 | 41.6 | 22.9 | 22.5 | 21.8
2007 | 616.0 | 200.2 | 134.4 | 42.4 | 22.3 | 22.0 | 22.1
| Standard error
1997 | 1.09 | 0.64 | 0.57 | 0.23 | 0.20 | 0.22 | 0.20
1998 | 1.06 | 0.63 | 0.54 | 0.23 | 0.20 | 0.21 | 0.20
1999 | 1.04 | 0.61 | 0.52 | 0.23 | 0.19 | 0.20 | 0.20
2000 | 1.02 | 0.60 | 0.51 | 0.23 | 0.19 | 0.20 | 0.19
2001 | 1.00 | 0.58 | 0.49 | 0.22 | 0.19 | 0.19 | 0.19
2002 | 0.98 | 0.57 | 0.48 | 0.23 | 0.19 | 0.19 | 0.18
2003 | 0.96 | 0.56 | 0.47 | 0.23 | 0.19 | 0.18 | 0.18
2004 | 0.94 | 0.54 | 0.45 | 0.23 | 0.18 | 0.18 | 0.17
2005 | 0.93 | 0.53 | 0.44 | 0.23 | 0.18 | 0.18 | 0.18
2006 | 0.91 | 0.52 | 0.43 | 0.24 | 0.17 | 0.17 | 0.17
2007 | 0.90 | 0.51 | 0.42 | 0.24 | 0.17 | 0.17 | 0.17

Cause of death, 2007 | Number | Percent distribution
All causes | 471,796 | 100.0
Cancer | 153,338 | 32.5
Heart disease | 102,961 | 21.8
Unintentional injuries | 32,508 | 6.9
Diabetes | 17,057 | 3.6
CLRD | 16,930 | 3.6
Stroke | 16,885 | 3.6
All other causes | 132,117 | 28.0

NOTES: CLRD is chronic lower respiratory diseases. Causes of death shown are the six leading causes of death among persons 45–64 years of age in 2007. Death rates for 1997–1998 are based on the International Classification of Diseases, 9th Revision. Starting in 1999, death rates are based on the International Classification of Diseases, 10th Revision. Comparability ratios for selected revisions are available from: http://www.cdc.gov/nchs/nvss/mortality/comparability_icd.htm. Cancer refers to malignant neoplasms. Stroke refers to cerebrovascular diseases. See Appendix II, Cause of death; Comparability ratio; Tables 35, 36, 38, 45, and 46.

SOURCE: CDC/NCHS, National Vital Statistics System. Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B.

Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

Data table for Figure 31 Death rates for leading causes of death among persons 65 years of age and over: United States, 1997–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig31.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig31.ppt)

Year | All causes | Heart disease | Cancer | Stroke | Chronic lower respiratory diseases (CLRD) | Alzheimer’s disease | Diabetes | Influenza and pneumonia
| Deaths per 100,000 population
1997 | 5,025.6 | 1,764.2 | 1,113.1 | 406.9 | 274.4 | † | 137.5 | †
1998 | 5,064.3 | 1,749.5 | 1,109.7 | 400.8 | 282.7 | † | 141.5 | †
1999 | 5,165.1 | 1,745.1 | 1,121.1 | 427.0 | 310.7 | 126.5 | 149.0 | 164.6
2000 | 5,143.6 | 1,696.7 | 1,121.3 | 423.1 | 304.0 | 140.0 | 149.8 | 167.3
2001 | 5,096.0 | 1,651.2 | 1,105.7 | 409.4 | 302.9 | 150.9 | 152.2 | 157.3
2002 | 5,088.8 | 1,618.7 | 1,098.3 | 402.5 | 304.2 | 163.7 | 153.7 | 165.2
2003 | 5,023.4 | 1,568.5 | 1,082.7 | 384.6 | 303.8 | 174.9 | 152.9 | 160.6
2004 | 4,837.4 | 1,469.4 | 1,063.1 | 359.7 | 289.8 | 180.0 | 148.7 | 145.4
2005 | 4,860.5 | 1,443.1 | 1,055.5 | 336.7 | 306.4 | 192.6 | 150.1 | 150.7
2006 | 4,722.0 | 1,370.2 | 1,040.0 | 314.0 | 286.8 | 192.3 | 140.5 | 132.4
2007 | 4,633.6 | 1,309.4 | 1,028.6 | 306.1 | 289.2 | 194.8 | 136.0 | 121.3
| Standard error
1997 | 3.82 | 2.26 | 1.80 | 1.09 | 0.89 | † | 0.63 | †
1998 | 3.82 | 2.25 | 1.79 | 1.08 | 0.90 | † | 0.64 | †
1999 | 3.85 | 2.24 | 1.79 | 1.11 | 0.94 | 0.60 | 0.65 | 0.69
2000 | 3.83 | 2.20 | 1.79 | 1.10 | 0.93 | 0.63 | 0.65 | 0.69
2001 | 3.80 | 2.16 | 1.77 | 1.08 | 0.93 | 0.65 | 0.66 | 0.67
2002 | 3.78 | 2.13 | 1.76 | 1.06 | 0.92 | 0.68 | 0.66 | 0.68
2003 | 3.74 | 2.09 | 1.74 | 1.03 | 0.92 | 0.70 | 0.65 | 0.67
2004 | 3.65 | 2.01 | 1.71 | 1.00 | 0.89 | 0.70 | 0.64 | 0.63
2005 | 3.63 | 1.98 | 1.69 | 0.96 | 0.91 | 0.72 | 0.64 | 0.64
2006 | 3.56 | 1.92 | 1.67 | 0.92 | 0.88 | 0.72 | 0.61 | 0.60
2007 | 3.50 | 1.86 | 1.65 | 0.90 | 0.87 | 0.72 | 0.60 | 0.57

Cause of death, 2007 | Number | Percent distribution
All causes | 1,755,567 | 100.0
Heart disease | 496,095 | 28.3
Cancer | 389,730 | 22.2
Stroke | 115,961 | 6.6
CLRD | 109,562 | 6.2
Alzheimer’s disease | 73,797 | 4.2
Diabetes | 51,528 | 2.9
Influenza and pneumonia | 45,941 | 2.6
All other causes | 472,953 | 26.9

† Data not comparable.

NOTES: Causes of death shown are the seven leading causes of death among persons 65 years of age and over in 2007. Death rates for 1997–1998 are based on the International Classification of Diseases, 9th Revision (ICD–9). Starting in 1999, death rates are based on the International Classification of Diseases, 10th Revision (ICD–10). Comparability ratios for selected revisions are available from: http://www.cdc.gov/nchs/nvss/mortality/comparability_icd.htm. Data for 1997–1998 for Alzheimer’s disease and Influenza and pneumonia are not presented due to large differences in death rates caused by changes in the coding of these causes between ICD–9 and ICD–10. Stroke refers to cerebrovascular diseases. See Appendix II, Cause of death; Comparability ratio; Tables 35, 36, 38, 45, and 46.

SOURCE: CDC/NCHS, National Vital Statistics System. Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B.

Deaths: Final data for 2007. National vital statistics reports; vol 58 no 19. Hyattsville, MD: NCHS; 2010. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr58_19.pdf.

Data table for Figure 32 Unintentional motor-vehicle traffic death rates by state: United States, average annual 2000–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig32.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig32.ppt)

State | 2000–2007 | State | 2000–2007
| Deaths per 100,000 population | | Deaths per 100,000 population
United States | 14.7 | Alaska | 14.9
Mississippi | 30.6 | Indiana | 14.9
Wyoming | 25.7 | Colorado | 14.7
Montana | 24.9 | Wisconsin | 14.2
Arkansas | 24.7 | Iowa | 14.1
Alabama | 24.6 | Maine | 13.8
South Carolina | 23.8 | Utah | 13.2
New Mexico | 22.5 | Oregon | 13.2
South Dakota | 21.9 | Virginia | 12.9
Louisiana | 21.9 | Michigan | 12.6
Tennessee | 21.8 | Pennsylvania | 12.5
Kentucky | 20.9 | Vermont | 12.3
West Virginia | 20.9 | Maryland | 12.1
Oklahoma | 20.6 | Ohio | 12.0
North Carolina | 19.3 | Minnesota | 12.0
Missouri | 19.2 | California | 11.7
Idaho | 19.0 | Illinois | 11.5
Arizona | 19.0 | Washington | 11.2
Florida | 18.4 | New Hampshire | 10.4
Georgia | 17.8 | Hawaii | 10.3
Kansas | 17.7 | Connecticut | 9.1
Texas | 17.2 | New Jersey | 8.7
Nevada | 16.7 | District of Columbia | 8.3
North Dakota | 16.5 | Rhode Island | 8.1
Nebraska | 15.6 | New York | 7.8
Delaware | 15.2 | Massachusetts | 7.4

NOTES: Rates are per 100,000 population and are age-adjusted to the year 2000 standard population. States listed are where the deaths occurred, not state of residence. Rates are rounded to whole numbers and plotted as quartiles.

SOURCE: CDC/NCHS. National Vital Statistics System.

Data table for Figure 33 Place of death, over time: United States, 1989, 1997, and 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig33.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig33.ppt)

Age and year | Place of death
Age and year | Nursing home | Hospital inpatient | Hospital outpatient or emergency department | Home | All other places
| Percent
All ages
1989 | 16.0 | 48.6 | 7.9 | 15.9 | 11.6
1997 | 21.4 | 41.5 | 8.1 | 22.3 | 6.8
2007 | 21.7 | 36.0 | 7.0 | 25.4 | 9.9
Under 65 years
1989 | 2.7 | 48.3 | 12.4 | 17.9 | 18.8
1997 | 4.5 | 42.1 | 13.5 | 26.2 | 13.7
2007 | 5.3 | 37.8 | 12.1 | 29.9 | 14.9
65 years and over
1989 | 21.3 | 48.7 | 6.2 | 15.2 | 8.7
1997 | 27.2 | 41.3 | 6.2 | 20.9 | 4.4
2007 | 27.9 | 35.3 | 5.0 | 23.7 | 8.0
| Standard error
All ages
1989 | 0.02 | 0.03 | 0.02 | 0.02 | 0.02
1997 | 0.03 | 0.03 | 0.02 | 0.03 | 0.02
2007 | 0.03 | 0.03 | 0.02 | 0.03 | 0.02
Under 65 years
1989 | 0.02 | 0.09 | 0.04 | 0.05 | 0.06
1997 | 0.03 | 0.06 | 0.04 | 0.06 | 0.04
2007 | 0.03 | 0.06 | 0.04 | 0.06 | 0.04
65 years and over
1989 | 0.04 | 0.06 | 0.02 | 0.03 | 0.02
1997 | 0.03 | 0.04 | 0.02 | 0.03 | 0.02
2007 | 0.03 | 0.04 | 0.02 | 0.03 | 0.02

NOTES: Persons were classified based on where death was pronounced and on the physical location of death, not the services they were receiving at the time of death. “All other places” includes dead on arrival, hospice facility, other, and unknown. Place of death was unknown for fewer than 2% of all deaths. Place of death data were collected using two different versions of the death certificate. The U.S. Standard Certificate of Death (which is used as a model by the states) was revised in 2003. This table includes 2007 data for the 23 states and the District of Columbia (representing about 50% of all deaths) that used the 2003 revision of the U.S. Standard Certificate of Death, and 2007 data for the remaining 27 states that collected and reported death data based on the 1989 revision of the U.S. Standard Certificate of Death. Data for 1989 and 1997 were collected using the 1989 revision of the Certificate of Death. The 2003 Certificate added “Hospice facility” as a check box item for place of death and “Long-term care facility” was added to the “Nursing home” check box. “Long-term care facility” and “Hospice facility” reflect changes in terminology and place of care. See Appendix I, Population Census and Population Estimates.

SOURCE: CDC/NCHS, National Vital Statistics System.

Data table for Figure 34 Place of death, by age and race and Hispanic origin: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig34.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig34.ppt)

Age and race and Hispanic origin | Place of death
Age and race and Hispanic origin | Nursing home | Hospital inpatient | Hospital outpatient or emergency department | Home | All other places
Age | Percent
All ages:
Hispanic or Latino | 10.6 | 44.4 | 8.9 | 24.4 | 11.7
Not Hispanic or Latino:
White | 24.0 | 33.9 | 6.1 | 26.2 | 9.8
Black or African American | 13.6 | 43.9 | 11.7 | 20.7 | 10.1
Asian or Pacific Islander | 12.7 | 46.9 | 8.3 | 23.9 | 8.2
American Indian or Alaska Native | 12.2 | 39.4 | 9.2 | 25.5 | 13.7
Under 65 years:
Hispanic or Latino | 3.4 | 45.5 | 12.8 | 21.5 | 16.8
Not Hispanic or Latino:
White | 5.7 | 34.4 | 11.0 | 34.0 | 14.8
Black or African American | 5.2 | 45.0 | 15.7 | 20.0 | 14.0
Asian or Pacific Islander | 3.9 | 47.5 | 12.2 | 23.7 | 12.6
American Indian or Alaska Native | 4.5 | 38.2 | 11.8 | 25.0 | 20.5
65 years and over:
Hispanic or Latino | 16.4 | 43.6 | 5.6 | 26.9 | 7.5
Not Hispanic or Latino:
White | 29.6 | 33.8 | 4.6 | 23.8 | 8.3
Black or African American | 20.3 | 43.0 | 8.5 | 21.3 | 6.8
Asian or Pacific Islander | 16.8 | 46.6 | 6.6 | 23.9 | 6.1
American Indian or Alaska Native | 20.4 | 40.7 | 6.5 | 26.0 | 6.4
Race and Hispanic origin | Standard error
All ages:
Hispanic or Latino | 0.08 | 0.13 | 0.08 | 0.12 | 0.09
Not Hispanic or Latino:
White | 0.03 | 0.03 | 0.02 | 0.03 | 0.02
Black or African American | 0.06 | 0.09 | 0.06 | 0.08 | 0.06
Asian or Pacific Islander | 0.16 | 0.24 | 0.13 | 0.20 | 0.13
American Indian or Alaska Native | 0.28 | 0.42 | 0.25 | 0.37 | 0.29
Under 65 years:
Hispanic or Latino | 0.07 | 0.20 | 0.14 | 0.17 | 0.15
Not Hispanic or Latino:
White | 0.03 | 0.07 | 0.05 | 0.07 | 0.05
Black or African American | 0.06 | 0.14 | 0.10 | 0.11 | 0.10
Asian or Pacific Islander | 0.16 | 0.42 | 0.28 | 0.36 | 0.28
American Indian or Alaska Native | 0.25 | 0.58 | 0.36 | 0.51 | 0.48
65 years and over:
Hispanic or Latino | 0.14 | 0.18 | 0.08 | 0.16 | 0.10
Not Hispanic or Latino:
White | 0.04 | 0.04 | 0.02 | 0.03 | 0.02
Black or African American | 0.10 | 0.12 | 0.07 | 0.10 | 0.06
Asian or Pacific Islander | 0.21 | 0.28 | 0.14 | 0.24 | 0.14
American Indian or Alaska Native | 0.50 | 0.60 | 0.30 | 0.54 | 0.30

NOTES: Persons were classified based on where death was pronounced and on the physical location of death, not the services they were receiving at the time of death. “All other places” includes dead on arrival, hospice facility, other, and unknown. Place of death was unknown for fewer than 2% of all deaths. Place of death data were collected using two different versions of the death certificate. The U.S. Standard Certificate of Death (which is used as a model by the states) was revised in 2003. This table includes 2007 data for the 23 states and the District of Columbia (representing about 50% of all deaths) that used the 2003 revision of the U.S. Standard Certificate of Death, and 2007 data for the remaining 27 states that collected and reported death data based on the 1989 revision of the U.S. Standard Certificate of Death. The 2003 Certificate added “Hospice facility” as a check box item for place of death and “Long-term care facility” was added to the “Nursing home” check box. “Long-term care facility” and “Hospice facility” reflect changes in terminology and place of care. See Appendix I, Population Census and Population Estimates.

SOURCE: CDC/NCHS, National Vital Statistics System.

Data table for Figure 35 Average number of days in ICU/CCU for Medicare decedents in the last 6 months of life, by state of residence: United States, 2005

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig35.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig35.ppt)

State of residence | Mean | State of residence | Mean
United States | 3.47 | Hawaii | 2.83
New Jersey | 5.71 | Arkansas | 2.73
Florida | 5.42 | Connecticut | 2.72
California | 4.69 | Nebraska | 2.72
Nevada | 4.19 | Mississippi | 2.61
Illinois | 4.09 | Rhode Island | 2.60
Texas | 4.08 | New Mexico | 2.47
Delaware | 3.92 | Oklahoma | 2.42
Pennsylvania | 3.86 | Massachusetts | 2.30
South Carolina | 3.74 | Kansas | 2.20
Arizona | 3.51 | Alaska | 2.18
District of Columbia | 3.51 | Washington | 2.18
Ohio | 3.51 | Colorado | 2.06
Virginia | 3.37 | Utah | 2.02
Kentucky | 3.36 | Montana | 1.88
Missouri | 3.36 | Minnesota | 1.84
Tennessee | 3.36 | South Dakota | 1.81
Louisiana | 3.32 | Iowa | 1.78
Michigan | 3.28 | Maine | 1.77
West Virginia | 3.25 | Wyoming | 1.77
Alabama | 3.22 | New Hampshire | 1.76
Georgia | 3.20 | Wisconsin | 1.69
New York | 3.17 | Idaho | 1.53
Maryland | 3.13 | Oregon | 1.51
Indiana | 3.11 | Vermont | 1.41
North Carolina | 3.02 | North Dakota | 1.34

NOTES: Includes Medicare enrollees who had full Part A and Part B entitlement throughout the last 6 months of life. Persons enrolled in managed care organizations (HMOs) were excluded. Restricted to those whose age on the date of death was 65–99 years. Geographic location is based on decedent’s residence, not place of care. Estimates were adjusted for differences in age, sex, and race.

SOURCE: The Dartmouth Atlas of Health Care. Available from: http://www.dartmouthatlas.org/.

Data table for Figure 36 Advance directives among adults 65 years of age and over, by type of care and race and Hispanic origin: United States, selected years

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig36.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig36.ppt)

Race and Hispanic origin | Type of care
Race and Hispanic origin | Nursing home residents | | Home health care patients | | Discharged hospice care patients
Race and Hispanic origin | 2004 | | 2007 | | 2007
Race and Hispanic origin | Percent | SE | Percent | SE | Percent | SE
Total | 69.9 | 0.8 | 35.0 | 2.2 | 91.7 | 1.0
Hispanic or Latino | 49.7 | 3.5 | *12.1 | *3.4 | 93.1 | 3.3
Not Hispanic or Latino:
White only | 74.8 | 0.7 | 42.2 | 2.6 | 92.9 | 1.0
Black or African American only | 40.5 | 2.1 | *12.4 | *2.7 | 79.1 | 5.3

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: For nursing home residents, advance directives include any of these orders: living will, do not resuscitate (dnr), do not hospitalize, feeding restrictions, medication restrictions, organ donation, or other. For home health care and discharged hospice care patients, advance directives include any of these orders: living will, do not resuscitate (dnr), do not hospitalize/do not send to emergency department, feeding restrictions, medication restrictions, comfort measures only, durable power of attorney, health care proxy/surrogate, organ donation, or other. The 2007 National Home and Hospice Care Survey data were collected through interviews with agency directors and their designated staffs; no interviews were conducted directly with patients or their families or friends. Data collected on home health care and hospice care patients are taken from medical records. For more information see: http://www.cdc.gov/nchs/data/nhhcsd/NHHCS_NHHAS_web_documentation.pdf. The 2004 National Nursing Home Survey data were collected through interviews with designated staff familiar with the residents and their care. The interviewed staff were asked to use the residents’ medical records to answer the data items. No interviews were conducted with residents. For more information see: http://www.cdc.gov/nchs/data/nnhsd/2004NNHS_DesignCollectionEstimates_072706tags.pdf. See Appendix I, National Home and Hospice Care Survey; National Nursing Home Survey; Appendix II, Resident, health facility.

SOURCE: CDC/NCHS, National Nursing Home Survey and National Home and Hospice Care Survey.

Data table for Figure 37 Selected characteristics of discharged hospice care patients: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig37.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig37.ppt)

Characteristic | 2007
Characteristic | Percent | SE
Age
Under 65 years | 16.9 | 0.8
65 years and over | 83.1 | 0.8
65–74 years | 15.4 | 1.1
75–84 years | 29.5 | 1.2
85 years and over | 38.2 | 1.3
Sex
Male | 44.9 | 1.4
Female | 55.1 | 1.4
Race and Hispanic origin
Hispanic or Latino | 4.1 | 0.7
Not Hispanic or Latino:
White | 86.6 | 1.2
Black or African American | 7.6 | 1.0
Marital status
Married or living with partner | 45.4 | 1.6
Single, divorced, or separated | 14.2 | 0.9
Widowed | 40.4 | 1.5
Vital status at discharge
Deceased | 84.4 | 1.1
Alive | 15.6 | 1.1
Medicare beneficiary
Yes | 84.3 | 0.9
No | 15.7 | 0.9
Place of care on first day
Private home | 55.3 | 1.7
Nursing home/skilled nursing facility | 21.1 | 1.4
Other place | 23.6 | 1.6

SE is standard error.

NOTES: There were 1.0 million hospice care discharges (weighted) in 2007. The 2007 National Home and Hospice Care Survey data were collected through interviews with agency directors and their designated staffs; no interviews were conducted directly with patients or their families or friends. Data collected on home health care patients and hospice care discharges are taken from medical records. For more information, see: http://www.cdc.gov/nchs/nhhcs/nhhcs_questionnaires.htm. Race and ethnicity of fewer than 2% of hospice care patient discharges were non-Hispanic Asian or American Indian or Alaska Native. These discharges are included in tabulations for characteristics other than race and Hispanic origin. The place of hospice care may change over the course of treatment. Data presented here are based on the place on the first day of hospice care. Other place includes residential care facility, inpatient hospice care agency, hospital, and other locations.

SOURCE: CDC/NCHS, National Home and Hospice Care Survey.

Data table for Figure 38 Primary admission diagnosis of discharged hospice care patients: United States, 1998 and 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig38.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig38.ppt)

Admission diagnosis | 1998 | | 2007 | | ICD–9–CM code
Admission diagnosis | Percent | SE | Percent | SE | ICD–9–CM code
Cancer (malignant neoplasms) | 64.8 | 2.5 | 42.9 | 1.5 | 140–208
Noncancer | 35.2 | 2.5 | 57.1 | 1.5 | All noncancer
Alzheimer’s, mental disorders, and other dementia | *3.1 | 0.6 | 11.2 | 0.9 | 290–319 or 331
Heart disease | 8.6 | 1.6 | 11.1 | 0.9 | 390–398, 402, 404, 410–429
CLRD (chronic lower respiratory diseases) | *3.5 | 0.9 | 4.8 | 0.5 | 490–494, 496
Stroke (cerebrovascular diseases) | *2.6 | 0.6 | 4.5 | 0.6 | 430–434, 436–438
All other | 17.4 | 2.0 | 25.6 | 1.1 | All other

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: ICD–9–CM is International Classification of Diseases, 9th Revision, Clinical Modification. The 2007 National Home and Hospice Care Survey data were collected through interviews with agency directors and their designated staffs; no interviews were conducted directly with patients or their families or friends. Data collected on home health care patients and hospice care discharges are taken from medical records. For more information see: http://www.cdc.gov/nchs/nhhcs/nhhcs_questionnaires.htm.

SOURCE: CDC/NCHS, National Home and Hospice Care Survey.

Data table for Figure 39 Services offered or provided to hospice care patients’ family members or friends: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig39.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig39.ppt)

Type of service | Percent | SE
Bereavement | 85.1 | 1.3
Spiritual | 66.8 | 2.2
Medication management or administration | 66.7 | 2.3
Patient activities of daily living | 58.1 | 2.2
Safety training | 53.3 | 2.5
Equipment use | 47.8 | 2.4
Caregiver health or wellness | 25.7 | 2.4
Dietary | 19.6 | 2.0
Referral or resource information | 19.1 | 2.2
Dealing with difficult behaviors | 17.8 | 1.9

SE is standard error.

NOTES: Data were collected through in-person interviews with agency directors and their designated staffs who were familiar with the patients and the care they received. Information was also abstracted from patients’ medical records. No information was obtained from family members or friends. Hospice staff were asked: “Did this agency offer or provide the patient’s family members or friends any of the services listed on this card? Which ones?”

SOURCE: CDC/NCHS, National Home and Hospice Care Survey.

Data table for Figure 40 Hospice care patients’ symptoms at the last hospice care visit before death: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig40.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig40.ppt)

Type of symptom | Percent | SE
Difficulty breathing | 50.7 | 2.0
Pain | 33.3 | 1.8
Restlessness | 25.0 | 1.7
Anorexia | 23.9 | 2.3
Constipation | 10.0 | 1.2

SE is standard error.

NOTES: Data were collected through in-person interviews with agency directors and their designated staffs who were familiar with the patients and the care they received. Information was also abstracted from patients’ medical records. No information was obtained from family members or friends. Data are based on the question: “When this agency last provided care to the patient did (he/she) have any of these symptoms before (his/her) death? Select all symptoms that apply.” This analysis is limited to those who died while under hospice care.

SOURCE: CDC/NCHS, National Home and Hospice Care Survey.

Data table for Figure 41 Selected drugs prescribed to hospice care patients in the last week of life: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus10figures/fig41.xls)

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig41.ppt)

Multum Lexicon Plus therapeutic class (common reasons for hospice use) | Percent | SE
Narcotic analgesic (severe pain) | 90.9 | 0.8
Antiemetic (vomiting or dizziness) | 78.6 | 1.5
Laxative (constipation) | 52.6 | 1.9
Antipsychotic (restlessness, agitation) | 36.1 | 1.8
Diuretic (fluid retention, high blood pressure, cardiac, kidney conditions) | 25.5 | 1.3
Proton pump inhibitor (antiulcer, antiitch) | 25.3 | 1.4
Bronchodilator (breathing difficulties) | 24.0 | 1.3
Antidepressant (depression, pain) | 23.4 | 1.3
Antacid (stomach acid, antiulcer) | 17.6 | 1.2
Antiarrythmic (heart rhythm disturbances) | 15.9 | 1.1
Corticosteroid (antiinflammatory, pain) | 14.2 | 1.0
Antidiabetic (elevated blood sugar) | 10.4 | 0.8
Antianginal (chest pain) | 7.4 | 0.7
Antihyperlipidemia (elevated cholesterol) | 7.1 | 0.7
Nonsteroidal antiinflammatory drug (inflammation, mild pain) | 6.7 | 0.7
Baby aspirin or Plavix (clopidogrel) (clot prevention) | 3.4 | 0.5

SE is standard error.

NOTES: Information is collected from the patient’s medical record based on the question: “What are the names of all the medications and drugs he/she was taking the 7 days prior to and on the the day of his/her death? Please include any standing routine, or PRN (as needed) medications.” Up to 25 medication names could be recorded. Information on dosage, strength, route, and frequency of administration was not recorded. Drug therapeutic class is based on Lexicon Plus, a proprietary database of Cerner Multum, Inc. Lexicon Plus is a comprehensive database of all prescription and some nonprescription drug products available in the U.S. drug market. Up to four classes are assigned to each drug. Data presented here are based on the second- level classification of prescription drugs except as noted: the category for narcotic analgesics is based on the first level, and the category for baby aspirin or Plavix is based on the third level. This analysis is limited to those patients who died while under hospice care.

SOURCE: CDC/NCHS, National Home and Hospice Care Survey.