# At a Glance Table

## Health, United States, 2010: At a Glance Table

| Value (year) | | | Health, United States Figure/Table no.
Life Expectancy and Mortality
Life expectancy in years | | | | Figure 1/Table 22
At birth | 76.8 (2000) | 77.7 (2006) | 77.9 (2007)
At age 65 years | 17.6 (2000) | 18.5 (2006) | 18.6 (2007)
Infant deaths per 1,000 live births | | | | Figure 25
All infants | 6.91 (2000) | 6.69 (2006) | 6.75 (2007)
Deaths per 100,000, age-adjusted | | | | Table 24
All causes | 869.0 (2000) | 776.5 (2006) | 760.2 (2007)
Heart disease | 257.6 (2000) | 200.2 (2006) | 190.9 (2007)
Cancer | 199.6 (2000) | 180.7 (2006) | 178.4 (2007)
Stroke | 60.9 (2000) | 43.6 (2006) | 42.2 (2007)
Chronic lower respiratory diseases | 44.2 (2000) | 40.5 (2006) | 40.8 (2007)
Unintentional injuries | 34.9 (2000) | 39.8 (2006) | 40.0 (2007)
Motor-vehicle | 15.4 (2000) | 15.0 (2006) | 14.4 (2007)
Diabetes | 25.0 (2000) | 23.3 (2006) | 22.5 (2007)
Morbidity and Risk Factors
Fair or poor health, percent | | | | Table 56
All ages | 8.9 (2000) | 9.9 (2008) | 9.9 (2009)
65 years and over | 26.9 (2000) | 24.9 (2008) | 24.0 (2009)
Heart disease, percent | | | | Table 49
18 years and over | 10.9 (1999–2000) | 11.4 (2005–2006) | 11.8 (2008–2009)
65 years and over | 29.6 (1999–2000) | 31.2 (2005–2006) | 31.7 (2008–2009)
Cancer (ever had), percent | | | | Table 49
18 years and over | 4.9 (1999–2000) | 5.7 (2005–2006) | 6.1 (2008–2009)
65 years and over | 15.2 (1999–2000) | 17.1 (2005–2006) | 17.7 (2008–2009)
Diabetes,^1^ percent | | | | Figure 5/Table 66
20 years and over | 8.5 (1999–2000) | 10.7 (2005–2006) | 11.9 (2007–2008)
Hypertension,^2^ percent | | | | Figure 15/Table 66
20 years and over | 28.9 (1999–2000) | 31.7 (2005–2006) | 32.6 (2007–2008)
High serum total cholesterol,^3^ percent | | | | Figure 16/Table 66
20 years and over | 17.7 (1999–2000) | 15.9 (2005–2006) | 14.6 (2007–2008)
Obese, percent | | | | Figures 13 and 14/Table 66
Obese,^4^ 20 years and over | 29.9 (1999–2000) | 34.2 (2005–2006) | 33.7 (2007–2008)
Obese (BMI at or above sex- and age-specific 95th percentile)
2–5 years | 10.3 (1999–2000) | 11.0 (2005–2006) | 10.4 (2007–2008)
6–11 years | 15.1 (1999–2000) | 15.1 (2005–2006) | 19.6 (2007–2008)
12–19 years | 14.8 (1999–2000) | 17.8 (2005–2006) | 18.1 (2007–2008)
Cigarette smoking, percent | | | | Figure 11/Table 58
18 years and over | 23.2 (2000) | 20.6 (2008) | 20.6 (2009)
Aerobic activity and muscle strengthening,^5^ percent | | | | Figure 12/Table 70
18 years and over | 15.1 (2000) | 18.1 (2008) | 18.8 (2009)
Health Care Utilization
No health care visit in past 12 months, percent | | | | Table 79
Under 18 years | 12.3 (2000) | 10.1 (2008) | 9.1 (2009)
18–44 years | 23.5 (2000) | 22.7 (2008) | 22.7 (2009)
45–64 years | 15.0 (2000) | 14.4 (2008) | 15.4 (2009)
65 years and over | 7.5 (2000) | 5.6 (2008) | 4.7 (2009)
Emergency room visit in past 12 months, percent | | | | Tables 88 and 89
Under 18 years | 20.3 (2000) | 20.9 (2008) | 20.8 (2009)
18–44 years | 20.5 (2000) | 21.5 (2008) | 22.0 (2009)
45–64 years | 17.6 (2000) | 17.6 (2008) | 18.4 (2009)
65 years and over | 23.7 (2000) | 23.4 (2008) | 24.9 (2009)
Dental visit in past year, percent | | | | Table 93
2–17 years | 74.1 (2000) | 77.3 (2008) | 78.4 (2009)
18–64 years | 65.1 (2000) | 60.4 (2008) | 62.0 (2009)
65 years and over | 56.6 (2000) | 57.6 (2008) | 59.6 (2009)
Prescription drug in past month, percent | | | | Table 94
Under 18 years | 24.1 (1999–2000) | 23.9 (2001–2004) | 25.3 (2005–2008)
18–44 years | 34.7 (1999–2000) | 37.6 (2001–2004) | 37.8 (2005–2008)
45–64 years | 62.1 (1999–2000) | 66.2 (2001–2004) | 64.8 (2005–2008)
65 years and over | 83.9 (1999–2000) | 87.3 (2001–2004) | 90.1 (2005–2008)
Hospitalization in past year, percent | | | | Table 98
18–44 years | 7.0 (2000) | 6.4 (2008) | 6.7 (2009)
45–64 years | 8.4 (2000) | 7.9 (2008) | 8.5 (2009)
65 years and over | 18.2 (2000) | 17.5 (2008) | 17.1 (2009)
Insurance and Access to Care
Uninsured, percent | | | | Figures 21 and 22/Table 138
Under 65 years | 17.0 (2000) | 16.8 (2008) | 17.5 (2009)
Under 18 years | 12.6 (2000) | 9.0 (2008) | 8.2 (2009)
18–44 years | 22.4 (2000) | 24.4 (2008) | 25.9 (2009)
45–64 years | 12.6 (2000) | 13.6 (2008) | 14.6 (2009)
Delayed or did not receive needed medical care due to cost, percent | | | | Figure 19/Table 76
Under 18 years | 4.6 (2000) | 5.4 (2008) | 5.2 (2009)
18–44 years | 9.5 (2000) | 13.6 (2008) | 15.1 (2009)
45–64 years | 8.8 (2000) | 13.5 (2008) | 15.1 (2009)
65 years and over | 4.5 (2000) | 4.5 (2008) | 5.1 (2009)
Health Care Resources
Physicians in patient care per 10,000 population | | | | Table 106
United States | 22.7 (2000) | 25.3 (2007) | 25.7 (2008)
Highest state (postal code) | 34.4 (MA) (2000) | 39.1 (MA) (2007) | 39.7 (MA) (2008)
Lowest state (postal code) | 14.4 (ID) (2000) | 17.0 (ID) (2007) | 17.0 (ID) (2008)
Community hospital beds per 1,000 population | | | | Table 115
United States | 2.9 (2000) | --- | 2.7 (2008)
Highest state (postal code) | 6.0 (ND) (2000) | --- | 5.4 (ND) (2008)
Lowest state (postal code) | 1.9 (NM,NV, OR,UT,WA) (2000) | --- | 1.7 (WA) (2008)
Expenditures
Personal health care expenditures, dollars | | | | Figure 23/Table 126
Total in trillions | $1.1 (2000) | $1.9 (2007) | $2.0 (2008)
Per capita | $4,032 (2000) | $6,186 (2007) | $6,411 (2008)

--- Data not available.

1 Diabetes prevalence is based on report of a physician diagnosis, or a fasting blood glucose of 126 mg/dL or higher, or a hemoglobin A1c of 6.5% or higher.

2 Having elevated blood pressure (measured) and/or taking antihypertensive medications.

3 Having cholesterol of 240 mg/dL or greater.

4 Obesity is a body mass index greater than or equal to 30 kg/m^2^. Height and weight are measured.

5 Meeting 2008 federal guidelines for aerobic activity and muscle strengthening.

NOTES: Some estimates are from the Excel spreadsheet version of the cited table and are not shown in the PDF version or in the printed version. For more information, data sources, notes, and the Excel version of the spreadsheet, see the complete report, Health, United States, 2010, available from: http://www.cdc.gov/nchs/hus.htm.