# Appendix III Additional Data Years Available

For Trend Tables spanning long periods, only selected data years are shown, to highlight major trends. Additional years of data for some of these tables are available in electronic spreadsheet form on the Health, United States, 2010 website at: http://www.cdc.gov/nchs/hus.htm. Standard errors are included in the spreadsheet files for tables that are based on the National Health Interview Survey, the National Health and Nutrition Examination Survey, and the National Survey of Family Growth.

Table number | Table topic | Additional data years available
1 | Resident population | 2001–2005
2 | Poverty | 1986–1989, 1991–1994, 1996–1999, 2001–2003, 2005–2006
3 | Fertility rates and birth rates | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004
4 | Live births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2005
5 | Prenatal care | 1975, 1981–1989, 1991–1999, 2001–2002
6 | Teenage childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2003
7 | Nonmarital childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2003
8 | Maternal smoking | 1991–1994, 1996–1999, 2001–2002
9 | Low birthweight | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001–2004
10 | Low birthweight | 1991–1999, 2001
12 | Abortions | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001–2002, 2005
13 | Contraceptive use | 1998
15 | Infant mortality rates | 1996–1999, 2001–2003
16 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001–2003
17 | Infant mortality rates | 1981–1989, 1991–1994, 1996–1999
20 | International mortality rates and rankings | 2001, 2002–2005; ranking 2005–2006
21 | International life expectancy | 1999, 2001–2003, 2005–2006
22 | Life expectancy | 1975, 1981–1989, 1991–1994, 1996–1998
24 | Age-adjusted death rates for selected causes | 1981–1989, 1991–1999, 2001–2004
25 | Years of potential life lost | 1991–1999, 2001–2006; crude 1999–2006
28 | Urbanization level | 2002–2004, 2003–2005, 2004–2006
29 | Death rates for all causes | 1981–1989, 1991–1999, 2001–2005
30 | Diseases of heart | 1981–1989, 1991–1999, 2001–2005
31 | Cerebrovascular diseases | 1981–1989, 1991–1999, 2001–2005
32 | Malignant neoplasms | 1981–1989, 1991–1999, 2001–2005
33 | Malignant neoplasms of trachea, bronchus, and lung | 1981–1989, 1991–1999, 2001–2005
34 | Malignant neoplasm of breast | 1981–1989, 1991–1999, 2001–2005
35 | Human immunodeficiency virus (HIV) disease | 1988–1989, 1991–1994, 2001–2004
36 | Maternal mortality | 1981–1989, 1991–1999, 2001–2004
37 | Motor vehicle-related injuries | 1981–1989, 1991–1999, 2001–2005
38 | Homicide | 1981–1989, 1991–1999, 2001–2005
39 | Suicide | 1981–1989, 1991–1999, 2001–2005
40 | Firearm-related injuries | 1981–1989, 1991–1994, 1996–1999, 2001–2004
41 | Occupational diseases | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004
43 | Nonfatal occupational injuries and illnesses | 2004–2005
44 | Notifiable diseases | 1985, 1988–1989, 1991–1999, 2001–2004
46 | Health conditions among children | 2006–2008
47 | Cancer incidence rates | 1991–1994, 1996–1999, 2001
48 | Five-year relative cancer survival rates | 1978–1980, 1984–1986, 1990–1992, 1993–1995
49 | Respondent-reported prevalence of heart disease, cancer, and stroke | 2001–2002, 2003–2004, 2007–2008
50 | Diabetes | 2001–2004
51 | End-stage renal disease | 1985, 1995, 2001–2005
52 | Severe headache or migraine, low back pain, and neck pain | 1998–2007
53 | Joint pain | 2003–2007
54 | Basic actions difficulty and complex activity limitation | 1998–1999, 2000–2006
55 | Vision and hearing limitations | 1998–1999, 2001–2006
56 | Respondent-assessed health status | 1998–1999, 2001–2004, 2006
57 | Serious psychological distress | 2000–2001, 2002–2003, 2003–2004, 2006–2007
58 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001–2004, 2006
59 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001–2004, 2006
60 | Cigarette smoking | 1993–1995, 2006–2008
61 | Use of selected substances | 2003–2005
62 | Use of selected substances | 1981–1984, 1986–1989, 1992–1994, 1996–1999, 2001–2005
63 | Health risk behaviors among students | 1993, 1995, 1997, 1999, 2001, 2003, 2005
64 | Lifetime alcohol drinking status | 1998–1999, 2001–2007
65 | Heavier drinking and drinking five or more drinks in a day | 1998–1999, 2001–2007
67 | Hypertension (high blood pressure) | 2001–2004
68 | Cholesterol | 2001–2004, 2003–2006
69 | Mean energy and macronutrient intake | 2003–2006
70 | Leisure-time aerobic/muscle-strengthing physical activity | 1999, 2001–2008
71 | Overweight, obesity, and healthy weight | 2001–2004
72 | Overweight among children and adolescents | 2001–2004, 2003–2006
73 | Untreated dental caries | 1999–2002
74 | No usual source of health care | 1995–1996, 1997–1998, 2001–2002, 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2007–2008
75 | No usual source of health care | 2003–2004, 2004–2005, 2005–2006, 2006–2007
76 | Reduced access to medical care | 1998–2007
77 | Reduced access to medical care | 19981999, 1999–2000, 2000–2001, 2002–2003, 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2007–2008
78 | No heath care visits | 1999–2000, 2003–2004, 2004–2005, 2005–2006, 2006–2007
79 | Health care visits | 1998–2007
81 | Vaccinations | 1996–1999, 2001–2003
82 | Vaccinations | 2003
84 | Influenza vaccination | 1991, 1993–1994, 1997–1999, 2001–2004
85 | Pneumococcal vaccination | 1991, 1993–1994, 1997–1999, 2001–2004
86 | Mammography | 1991, 1998
87 | Pap smears | 1998
88 | Emergency department visits for children | 1998–2007
89 | Emergency department visits for adults | 1998–1999, 2001–2007
90 | Injury-related visits to hospital emergency departments | 2005–2006, 2006–2007
91 | Ambulatory care visits | 1997–1999, 2001–2006
92 | Ambulatory care visits | 1997–1999, 2001–2007
93 | Dental visits | 1998–2007
94 | Prescription drug use | 1999–2000, 1999–2002, 2001–2004, 2003–2006
96 | Dietary supplement use | 2001–2004, 2003–2005
97 | Additions to mental health organizations | 1992, 1994, 1998, 2000
98 | Discharges | 1998–1999, 2001–2007
99 | Discharges | 1991–1994, 1996–1999, 2001–2004
100 | Days of care | 1991–1999, 2001–2006
101 | Diagnoses | 1991–1999, 2001–2006
102 | Average length of stay | 1991–1999, 2001–2006
103 | Procedures | 1991–1999, 2001–2006
105 | Persons employed in health service sites | 2001–2002
110 | Employees and wages | 2002, 2004–2005, 2007–2008
114 | Mental health organizations | 1992
117 | Nursing homes | 1996–1999, 2001–2007
118 | Certified intermediate care facilities | 2000, 2007
119 | Medicare-certified providers and suppliers | 1997–1998, 2002, 2004, 2006
120 | Magnetic Resonance Imaging (MRI) units and Computed Tomography (CT) scanners | 2001–2002
121 | Total health expenditures as a percent of gross domestic product | 1961–1969, 1971–1979, 1981–1989, 1991–1994, 1996–1999, 2001–2002
122 | Gross domestic product | 2005
126 | Personal health care expenditures | 2005
128 | Expenditures for mental health services | 1987–1989, 1991–1994, 1996–1999, 2001–2003
129 | Expenditures for substance abuse treatment | 1987–1989, 1991–1994, 1996–1999, 2001
130 | Expenditures for health care | 1996, 1998–1999, 2001–2006
131 | Sources of payment for health care | 1996, 1998–1999, 2001–2006
132 | Out-of-pocket health care expenses | 1997–1999, 2001–2003
133 | Expenditures for health services and supplies | 2003
134 | Employers’ costs and health insurance | 1992–1993, 1995, 1997–1999, 2001–2005
135 | Private health insurance | 1994, 1998–1999, 2001–2004
136 | Private health insurance | 1994, 1999, 2001–2004, 2006
137 | Medicaid coverage | 1994, 1998–1999, 2001–2003, 2005–2006
138 | No health insurance coverage | 1994, 1998–1999, 2001–2003, 2005–2006
139 | Health care coverage | 1993–1994, 1996–1999, 2001–2005
141 | Medicare | 1996–1998, 2001, 2003–2004
142 | Medicare | All: 1999–2002; 1993–2003
143 | Medicaid | 2001
144 | Medicaid | 2001
145 | Department of Veterans Affairs | 1985, 1988–1989, 1991–1994, 1996–1999, 2001–2004
146 | Medicare | 1995–2006
147 | Medicaid | 2001–2007
148 | Persons without health insurance coverage | 2004–2006, 2005–2007