# Access to Care

## Delay or Nonreceipt of Needed Medical Care Due to Cost

Between 1999 and 2009, the percentage of working-age adults who delayed or did not receive needed medical care due to cost increased among persons with private coverage and among the uninsured.

Delaying or not receiving needed medical care may result in more serious illness, increased complications, and longer hospital stays (1,2). Persons with limited access to medical care, such as the uninsured, are more likely to delay or fail to obtain medical care when needed (3).

Among adults 18–64 years of age, the percentage who reported delaying or not receiving needed medical care in a 12-month period due to cost increased from 9% in 1999 to 15% in 2009. This increase was driven by a 72% increase in reported delay or nonreceipt of needed care among those with private insurance and a 41% increase among the uninsured.

Throughout this time period, delay or nonreceipt of needed medical care due to cost was highest among the uninsured and lowest among those with private coverage. In 2009, 37% of uninsured adults 18–64 years of age reported delay or nonreceipt of needed medical care due to cost, compared with 14% of those with Medicaid and 9% of privately insured adults.

Delay or nonreceipt of needed medical care due to cost also varied by age for adults with different types of coverage. Older working-age adults 45–64 years of age with Medicaid coverage or without insurance were more likely to report delaying or not receiving needed medical care due to cost than adults 18–44 years of age in the same insurance categories. Among those with private insurance coverage, older working-age adults did not report more problems in accessing care due to cost than younger adults.

Figure 19 Adults 18–64 years of age who delayed or did not receive needed medical care in the past 12 months due to cost, by age and type of health insurance coverage: United States, 1999–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig19.ppt)

NOTE: See data table for Figure 19.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 19 consists of two line graphs, one showing adults 18 through 44 years of age and one for adults 45 through 64 years of age, who delayed or did not receive needed medical care in the past 12 months due to cost, by type of health insurance coverage, for 1999 through 2009.

### References

1 Diamant AL, Hays RD, Morales LS, Ford W, Clames D, Asch S, et al. (2004). Delays and unmet need for health care among adult primary care patients in a restructured urban public health system. Am J Public Health.
2 Baker DW, Shapiro MF, Schur CL. (2000). Health insurance and access to care for symptomatic conditions. Arch Intern Med.
3 Institute of Medicine (US). (2001). Coverage matters: Insurance and health care.

## Dental Health Services Needs Unmet Due to Cost

From 1999 to 2009, the percentage of adults 18 years of age and over reporting unmet dental health care needs due to cost increased from 8% to 15%.

Oral health is integral to overall health. Poor oral health is associated with heart disease, stroke, and preterm, low-birthweight births (1). Poor oral health and its consequences may affect people’s daily lives by interfering with eating, sleeping, working, and learning. Many diseases and conditions manifest themselves with oral symptoms, and these early signs may be initially noted by dental care providers.

In 2009, working-age adults 18–44 and 45–64 years of age were more likely than children or older adults to report having unmet dental health care needs in the past 12 months because they could not afford care. Among working-age adults, women were more likely to report unmet dental health care needs than men. For children and older adults, the reported rates of unmet dental health care were similar for males and females.

Since 1999, there has been a significant increase in the percentage of adults reporting unmet dental health care needs due to cost. In 1999, 8% of adults reported that they did not receive needed dental health services within the past 12 months because they could not afford them. By 2009, this percentage had increased to 15% (data table for Figure 20).

Figure 20 Persons who did not receive needed dental services in the past 12 months due to cost, by sex and age: United States, 1999–2009

Click here for powerpoint slide (http://www.cdc.gov/nchs/ppt/hus/HUS10fig20.ppt)

NOTE: See data table for Figure 20.

SOURCE: CDC/NCHS, National Health Interview Survey.

Figure 20 consists of two line graphs, one for males and one for females, who did not receive needed dental services in the past 12 months due to cost, by age, for 1999 through 2009.

### Reference

1 U.S. Department of Health and Human Services. (2000). Oral health in America: A report of the Surgeon General—Executive summary.