# Population

## Age

As the number of Americans increases, more demands are placed on the Nation’s health care system.

The health status of the Nation, as well as its need for health care resources, is determined in part by the size and composition of its population. From 1980 to 2007, the U.S. population increased on average 1.1% per year (Figure 1A). In 2007, there were 302 million U.S. residents, up from 227 million in 1980 (see data table for Figures 1A and 1B). By 2050, the U.S. population is projected to reach 440 million.

Figure 1A Total population, by age: United States, 1980–2050

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig01.xls) Click here for powerpoint slide 1A (http://www.cdc.gov/nchs/ppt/hus/HUS09fig01a.ppt)

NOTE: See data table for Figure 1.

SOURCE: U.S. Census Bureau.

Figure 1B Percent distribution of the total population, by age: United States, 1980, 2007, 2050

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig01.xls) Click here for powerpoint slide 1B (http://www.cdc.gov/nchs/ppt/hus/HUS09fig01b.ppt)

NOTE: See data table for Figure 1.

SOURCE: U.S. Census Bureau.

Between 1980 and 2007, the population continued to age as the percentage of the U.S. middle-age population (45–64 years of age) increased from 20% to 25%, while the percentage under 18 years fell from 28% to 25% (Figure 1B). During this period, the percentage of the population of reproductive age (18–44 years) decreased from 41% to 38%. Among the older population, the percentage 65–74 years of age decreased slightly, from 7% to 6%, while the percentage of Americans 75 years of age and over increased from 4% to 6%.

From 2007 to 2050, the U.S. population is projected to grow older. The percentage of the population under 18 years of age is projected to remain at about 23%–25%, and the percentage of the population 18–44 and 45–64 years of age is projected to decline. In contrast, the percentage of the older population is projected to increase as the baby boomers (those born in the post-World War II period 1946–1964) continue to age. During this period, the percentage of the population 65–74 years of age is projected to increase from 6% to 9%, and the percentage 75 years of age and over projected to almost double, rising from 6% to 11%. As the population ages, the need and demand for health care will increase because older adults are more likely to suffer from chronic conditions and to seek medical care and other services associated with the aging process (Tables 54, 55, 58, 71, 101, and 131).

Population growth is the net result of the natural increase in population from births and international migration and the natural decrease in population from deaths and emigration. After declining sharply in the 1960s and 1970s, the Nation’s birth rate remained relatively stable between 1980 and 2006 (Table 4). The U.S. Census Bureau projects that the population under 1 year of age will increase progressively until 2050 (1). Children are more likely to live in poverty than any other age group (Figures 4 and 5).

Almost one-third of current population growth is estimated to be caused by net immigration (1). Between 1980 and 2004, the percentage of the U.S. population that was foreign-born doubled from 6% to 12% (2). The immigrant population is younger and disproportionately more likely to be low-income and uninsured (3). They are also more likely to face other barriers to accessing health care, including ineligibility for many government-sponsored programs and difficulty in finding providers who speak their language and provide culturally sensitive care (4).

Between 1980 and 2006, the age-adjusted all-cause mortality rate declined 25%, primarily due to steep declines in heart disease and stroke mortality (Figure 18). Life expectancy at birth increased by almost 4 years from 1980 to 2005 (Figure 16). Life expectancy has increased for all racial and ethnic groups, but substantial disparities persist (Table 24).

### References

1 Day JC. Population profile of the United States [online].
2 (2004). Foreign-born population of the United States: Current population survey—March 2004 [online]. Detailed tables (PPL–176).
3 Kaiser Commission on Medicaid and the Uninsured. (2003). Immigrants’ health care: Coverage and access [online].
4 Ku L, Matani S. (2001). Left out: Immigrants’ access to health care and insurance. Health Aff (Millwood).

## Race and Ethnicity

Between 1980 and 2008, there was substantial growth in the Hispanic and Asian populations in the United States.

The United States population is growing (Figure 1A and Figure 1B), and its racial and ethnic composition is changing. Changes in the racial and ethnic composition of the population have important consequences for the health of the Nation because many risk factors, behaviors, levels of disease prevalence and disability, and access to and utilization of health services differ substantially by race and ethnicity. Health insurance coverage—a major determinant of access to health care—differs significantly by racial and ethnic groups (Tables 137–141). Nearly one in three Hispanic persons under age 65 years is uninsured (Table 140). One of the overarching goals of U.S. public health policy is the elimination of racial and ethnic disparities in health.

Diversity has long been a characteristic of the U.S. population. In the past few decades, the racial and ethnic composition of the population under 18 years of age has changed. In 1980, 9% of children were of Hispanic origin and 2% were Asian. By 2008, the percentage of children in the Hispanic and Asian populations had more than doubled (Figure 2). Growth in the population of Hispanic children is fueled by higher birth rates (Table 4).

Figure 2 Population in selected race and Hispanic origin groups, by age: United States, 1980–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig2.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig2.ppt)

^1^Not Hispanic.

NOTES: Persons of Hispanic origin may be of any race. Race data for 2000 and beyond are not directly comparable with data for 1980 and 1990. Individuals could report only one race in 1980 and 1990 and more than one race in 2000 and beyond. Persons who selected only one race in 2000 and beyond are included in single-race categories; persons who selected more than one race in 2000 and beyond are shown as having 2 or more races and are not included in single-race categories. In 1980 and 1990, the Asian category included Asian and Native Hawaiian or Other Pacific Islander; in 2000 and beyond, this category includes only Asian. See data table for Figure 2.

SOURCE: U.S. Census Bureau.

The racial and ethnic composition of the adult population has also changed over time. Between 1980 and 2008, the percentage of adults who were Hispanic more than doubled, while the percentage of Asian adults tripled (Figure 2). Growth in the Hispanic and Asian adult populations is primarily due to immigration (1,2). The Hispanic and Asian populations are projected to continue to increase in the future; by 2050 they are estimated to comprise 25% and 8% of the total population, respectively (1).

In the 1980 and 1990 decennial censuses, persons could choose only one racial category to describe their race (3). Beginning with the 2000 census, the question on race was modified to allow the choice of more than one racial category (3). Although, overall, a small percentage (1%) of persons of non-Hispanic origin selected two or more races in 2008, the percentage of children described as being of more than one race was more than twice as high as the percentage of adults (Figure 2). The number of adults identifying themselves or their children as multiracial is expected to increase in the future (4). The percentage of persons reporting two or more races varies considerably across racial groups, with those of American Indian or Alaska Native origin more likely to report two or more races (3).

### References

1 Day JC. (1996). Population projections of the United States by age, sex, race, and Hispanic origin: 1995.
2 Riche MF. (2000). America’s diversity and growth: Signposts for the 21st century. Popul Bull.
3 Grieco EM, Cassidy RC. (2001). Overview of race and Hispanic origin. Census 2000 brief.
4 Waters MC. (2000). Immigration, intermarriage, and the challenges of measuring racial/ethnic identities. Am J Public Health.

## Living Veterans

In 2007, there were 24 million living veterans, 12% of whom were receiving compensation for service-connected disability.

Veterans may receive health care through a variety of sources, including private health insurance, Medicaid, Medicare, and the Department of Veterans Affairs (VA). Veterans with service-related disabilities, other disabilities, and those with low income are more likely to rely on VA services (1). Differences in usage of VA services reflect, in part, veterans’ qualifications for and access to other health care services. In addition, the VA classifies veterans into priority groups based on service-connected disabilities (SCDs), service-related exposures, Medicaid eligibility, income, and other factors (1,2). For example, veterans with an SCD rated 50% or more disabling are priority group 1, whereas veterans without SCD and with incomes and net worth above VA thresholds are priority group 8. Cost-sharing rules vary by priority group, and at times enrollment for those classified as priority group 8 has been frozen due to budgetary limitations.

Because of their military service, veterans may have specialized health care needs. Veterans who were injured during their service may need prosthetics, rehabilitation services, and other specialized follow-up care for traumatic injuries. Veterans may suffer from a variety of mental health conditions as a result of their service, including post-traumatic stress disorder (3) and the aftereffects of being prisoners of war (4). Veterans in a variety of arenas have been exposed to chemical agents that were later determined to cause health problems. These include World War II veterans who were exposed to the chemical weapons mustard gas and lewisite; such exposure has been linked to respiratory cancers and other chronic respiratory diseases, corneal conditions, and psychological disorders (5). Exposure to Agent Orange and other herbicides during the Vietnam era has been associated with Hodgkin and non-Hodgkin lymphoma and chronic lymphocytic leukemia (6). Studies of the health of Gulf War veterans found that about one-quarter of those serving in the Persian Gulf from 1990 to 1991 have had persistent health problems. A group of symptoms known as Gulf War illness has been linked to anti-nerve agents and pesticide exposure (7,8).

Because the need for health care services may be related to service-related exposures and conditions, data for veterans are often classified by their period of service. Of the 24 million living veterans in 2007, almost 5 million served during the Gulf War era (defined as any active duty from August 2, 1990 to present), almost 8 million had served in the Vietnam era, almost 3 million each had service during the Korean conflict and World War II, and another 6 million served during peacetime (veterans are classified by their earliest period of service). The percentage of living veterans receiving compensation for SCD reached a high of 12% in 2007 (Figure 3), up from 8% to 9% in the decades between 1970 and 2000 (data table for Figure 3).

Figure 3 Population of living veterans, by service-connected disability status: United States, 1970–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig3.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig3.ppt)

NOTES: Veterans with SCD are receiving financial compensation. See data table for Figure 3.

SOURCES: U.S. Department of Veterans Affairs and U.S. Census Bureau.

### References

1 Congressional Budget Office (CBO). (2007). The health care system for veterans: An interim report. Pub no 3016.
2 U.S. Department of Veterans Affairs. (2008). Enrollment priority groups. VA Health Care fact sheet 164–2.
3 Institute of Medicine. (2008). Treatment of posttraumatic stress disorder: An assessment of the evidence.
4 Institute of Medicine. (1992). The health of former prisoners of war: Results from the medical examination survey of former POWs of World War II and the Korean conflict.
5 Institute of Medicine. (1993). Veterans at risk: The health effects of mustard gas and lewisite.
6 Institute of Medicine. (2007). Veterans and Agent Orange: Update 2006.
7 Research Advisory Committee on Gulf War Veterans’ Illnesses. (2008). Gulf War illness and the health of Gulf War veterans: Scientific findings and recommendations.
8 Institute of Medicine. (2006). Gulf War and health. Health effects of serving in the Gulf War.

## Poverty

In 2007, Hispanic and black Americans in all age groups were more likely to live in poverty than white and Asian Americans.

Children and adults in families with income below or near the federal poverty level have worse health than those with higher income (Tables 57 and 58; see Appendix II, Poverty, for a definition of the federal poverty level). Although in some cases illness can lead to poverty, more often poverty is associated with poor health by its connection with inadequate nutrition, substandard housing, exposure to environmental hazards, unhealthy lifestyles, and decreased access to and use of health care services (1,2) (Tables 75–80).

In 2007, the percentage of the U.S. population living in poverty was 12.5%, unchanged from 2006 but higher than in 2000 at 11.3% (3). The poverty rate among children increased between 2006 and 2007 but remained unchanged among adults 18–64 years of age and 65 years and over (2) (data table for Figure 4).

Since 1974, children have been more likely than either working-age or older adults to live in poverty (Figure 4). In 2007, 13.3 million children (18.0%) lived in poverty and another 15.7 million children (21.2%) were classified as near poor, with a family income between 100% and 200% of the poverty level (data table for Figure 5). In 2007, children represented 35.7% of all Americans living in poverty but only 24.8% of the total population (3).

Prior to 1974, persons 65 years of age and over were more likely to be poor than people of other ages. With the increased benefits provided by government social insurance programs such as Social Security, the poverty rate of older adults declined rapidly until 1974 and then continued a gradual decline through 1999 (4). Between 1999 and 2007, poverty rates among older adults fluctuated around 10%. In 2007, 3.6 million persons 65 years and over (9.7%) lived in poverty, with an additional 9.7 million older persons (26.4%) classified as near poor (data table for Figure 5).

The poverty rate in 2007 was unchanged from 2006 levels for non-Hispanic white persons, black persons, and Asian persons, but increased for persons of Hispanic origin (3). At all ages, a higher percentage of Hispanic and black persons than non-Hispanic white persons were poor (Figure 5). In 2007, 29%–35% of Hispanic and black children were poor, compared with 10%–13% of non-Hispanic white and Asian children. Similarly, among persons 65 years of age and over, 17.1% of Hispanic and 23.2% of black persons were poor, compared with 7.4% of non-Hispanic white persons and 11.3% of Asian persons. In 2005–2007, 26.6% of American Indian or Alaska Native persons lived in poverty (5).

Figure 4 Poverty by age: United States, 1966–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig4.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig4.ppt)

NOTES: Data shown are the percentage of persons with family income below the poverty level. See data table for Figure 4.

SOURCE: U.S. Census Bureau, Current Population Survey, Annual Social and Economic Supplements.

Figure 5 Low income by age, race and Hispanic origin: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig5.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig5.ppt)

NOTES: Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Persons of Hispanic origin may be of any race. Black and Asian races include persons of Hispanic and non-Hispanic origin. See data table for Figure 5.

SOURCE: U.S. Census Bureau, Current Population Survey, Annual Social and Economic Supplements.

### References

1 Starfield B, Birn A-E. (2007). Income redistribution is not enough: Income inequality, social welfare programs, and achieving equity in health. J Epidemiol Community Health.
2 Marmot M. (2002). The influence of income on health: Views of an epidemiologist. Health Aff (Millwood).
3 DeNavas-Walt C, Proctor BD, Smith JC. (2008). Income, poverty, and health insurance coverage in the United States: 2007.
4 Clark RL, Quinn JF. (1999). The economic status of the elderly. Medicare Brief.
5 (2009). Current Population Survey (CPS) table creator for the Annual Social and Economic Supplement, 2006–2008 [online].