# Highlights

Health, United States, 2009 is the 33rd report on the health status of the Nation. The report contains a Chartbook and 150 trend tables presenting current and historic information on the health of the U.S. population. The trend tables are organized around four major subject areas: health status and determinants, health care utilization, health care resources, and health care expenditures and payors. The 2009 Chartbook focuses on selected determinants and measures of health and includes a special feature on medical technology.

## Population

The health status of the Nation, as well as its need for health care resources, is determined in part by the size and composition of its population.

In 2007 there were 302 million U.S. residents, up from 281 million in 2000 and 227 million in 1980 (data table for Figure 1).

Between 1980 and 2007, the percentage of Americans age 75 and over increased from 4% to 6% (Figure 1A and Figure 1B).

Between 1980 and 2008, the percentage of children who were Hispanic or Asian more than doubled. During the same period, the percentage of adults who were Hispanic more than doubled, and the percentage of adults who were Asian tripled (Figure 2).

In 2007, there were 24 million living veterans, 12% of whom were receiving compensation for service-connected disability (Figure 3).

## Fertility and Natality

Teenage mothers and their children are more likely to be disadvantaged and have a generally less favorable health status than older new mothers and their children. Low birthweight is a major correlate of infant illness and mortality.

Between 2005 and 2007 (preliminary data), the birth rate among teenagers 15–19 years of age rose 5%, from 40.5 to 42.5 live births per 1,000 females, with most of the increase occurring between 2005 and 2006. This 2-year increase follows a 14-year downward trend between 1991 and 2005 in which the teen birth rate fell by 34% from a peak of 61.8 births per 1,000 in 1991 (Table 4).

Low birthweight is associated with elevated risk of death and disability in infants. In 2007 (preliminary data), the percentage of low birthweight births (infants less than 2,500 grams (5.5 pounds) at birth) declined slightly to 8.2% from 8.3% in 2006. The 2007 percentage is 17% higher than for 1990 (7%) (Table 11).

## Life Expectancy and Mortality

As overall death rates have declined, racial and ethnic disparities in mortality have persisted, but the gap in life expectancy between the black and white populations has narrowed. Life expectancy at birth in the United States lags behind that in most other industrialized countries. Life expectancy and infant mortality are often used to gauge the overall health of a population. Life expectancy in this country shows a long-term upward trend, and infant mortality shows a long-term downward trend.

In 2007 (preliminary data), life expectancy at birth for the total population reached a record high of 77.9 years, up from 75.4 years in 1990 (Table 24).

Between 1990 and 2007 (preliminary data), life expectancy at birth increased 3.5 years for males and 1.6 years for females. The gap in life expectancy between males and females narrowed from 7.0 years in 1990 to 5.1 years in 2007 (preliminary data) (Table 24).

Between 1990 and 2007 (preliminary data), life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 1990, life expectancy at birth for the white population was 7.0 years longer than for the black population. By 2007 (preliminary data), the difference had narrowed to 4.6 years (Figure 16 and Table 24).

Among 37 countries and territories that submitted data to the Organisation for Economic Co-operation and Development (OECD) in 2005, life expectancy in the U.S. was below that of most other industrialized countries (Table 23).

Overall mortality was 25% higher for black Americans than for white Americans in 2007 (preliminary data), compared with 37% higher in 1990. In 2006, age-adjusted death rates for the black population exceeded those for the white population by 48% for stroke (cerebrovascular disease), 31% for heart disease, 21% for cancer (malignant neoplasms), 113% for diabetes, and 786% for HIV disease (Table 26).

In 2007 (preliminary data), the infant mortality rate was 6.77 infant deaths per 1,000 live births, 27% lower than in 1990 (Figure 17).

Large disparities in infant mortality rates among racial and ethnic groups continue to exist. In 2005, infant mortality rates were highest for infants of non-Hispanic black mothers (13.63 deaths per 1,000 live births), American Indian or Alaska Native mothers (8.06 per 1,000), and Puerto Rican mothers (8.30 per 1,000), and lowest for infants of Cuban (4.42 per 1,000), Central and South American (4.68 per 1,000), and Asian or Pacific Islander mothers (4.89 per 1,000) (Table 17 and National Vital Statistics Report, available from: http://www.cdc.gov/nchs/data/nvsr/nvsr57/nvsr57_02.pdf).

The leading cause of death differs by age group. In 2007 (preliminary data), the leading cause of death was unintentional injuries for people 1–44 years of age, cancer for adults 45–64 years of age, and heart disease for adults 65 years and over (Table 29).

Age-adjusted mortality from heart disease—the leading cause of death overall—declined 41% between 1990 and 2007 (preliminary data), continuing a long-term downward trend (Figure 18 and Table 32).

Age-adjusted mortality from cancer (malignant neoplasms)— the second leading cause of death overall—decreased 18% between 1990 and 2007 (preliminary data) (Figure 18 and Table 34).

The age-adjusted death rate for HIV disease has declined slowly since 1999, after a sharp decrease during the mid 1990s associated with the widespread adoption of highly active antiretroviral therapy (HAART). The death rate for HIV disease is higher for those 35–54 years of age than for other ages (Figure 35 and Table 38).

The homicide rate for black males 15–24 years of age decreased sharply from the early to the late 1990s and has remained relatively stable since then (Table 41).

## Health Risk Factors

Obesity increases the risk of heart disease, diabetes, and stroke. Heavy and chronic use of alcohol and use of illicit drugs increase the risk of disease and injuries. Cigarette smoking increases the risk of lung cancer, heart disease, emphysema, and other diseases. Regular physical activity reduces the risk of disease and enhances mental and physical functioning.

Between 1976–1980 and 2005–2006, the prevalence of overweight among preschool-age children 2–5 years of age more than doubled, from 5% to 11% (Figure 7).

The prevalence of overweight among school-age children and adolescents increased between 1976–1980 and 2005–2006. The prevalence of overweight more than doubled, from 7% to 15%, among children 6–11 years of age and more than tripled, from 5% to 18%, among adolescents 12–19 years (Table 73 and Figure 7).

Among adults 20–74 years of age, obesity rates have more than doubled since 1976–1980. From 1976–1980 to 2005–2006, the percentage of adults who were obese increased from 15% to 35% (age-adjusted) (Figure 7).

In 2007, 8% of people 12 years of age and over reported use of any illicit drugs in the past month, 6% reported marijuana use, and 3% reported nonmedical use of prescription drugs. Use of illicit drugs was higher among persons 16–25 years of age than for persons in other age groups (Table 63).

In 2007, 21% of adults 18 years of age and over reported having five or more drinks in a day at least once in the past year, and 9% reported having five or more drinks in a day at least 12 times in the past year (Table 66).

In 2007, 20% of U.S. adults were current cigarette smokers, only a slight decrease from 21% in the previous 3 years. Men were more likely to be current cigarette smokers than women (22% compared with 18%, age-adjusted) (Figure 6 and Table 60).

In 2005–2006, 30% of adults often or almost always had trouble sleeping in the past month (Figure 8).

## Measures of Health and Disability

Measures of health status presented in this report include respondent-assessed health status, prevalence of selected diseases and conditions, and mental health status. Measures of disability presented include prevalence of basic actions difficulty, complex activity limitations, and limitations in functioning associated with chronic health conditions.

In 2007, the percentage of noninstitutionalized adults reporting their health as fair or poor ranged from 6% of those 18–44 years of age to 31% of those 75 years and over. The proportion of all persons with fair or poor health was three times higher among persons living in poverty compared with those in higher income families (Table 57).

The prevalence of hypertension—defined as elevated blood pressure or taking antihypertensive medication—increases with age. In 2003–2006, 36% of men and women 45–54 years of age had hypertension, compared with 65% of men and 80% of women 75 years and over (Table 68).

The percentage of adults with diabetes (including both diagnosed and undiagnosed) increased from 1988–1994 (8%) to 2003–2006 (10%). Diabetes is more common among non-Hispanic black persons and Mexican Americans than among non-Hispanic white persons (Table 51).

Between 1988–1994 and 2003–2006, the percentage of both men and women 55 years of age and over with a high total serum cholesterol level (greater than or equal to 240 mg/dL) declined. However, older women were more likely to have high serum cholesterol than older men. In 2003–2006, 24% of women 65–74 years of age had high serum cholesterol, compared with 11% of men of the same age (Table 69).

From 1990 to 2006, the number of new cases of lung and bronchus cancer per 100,000 population declined on average 2% per year among males and remained unchanged among females. Cancer of the lung and bronchus is the second most common newly diagnosed cancer among males (after prostate cancer) and females (after breast cancer) (Table 49).

Between 1988–1994 and 2001–2004, approximately one-quarter of adults 20–64 years of age and children 6–19 years of age had untreated dental caries, down from approximately one-half in 1971–1974 (Table 74).

In 2007, approximately 2.0 million nonfatal workplace injuries and illnesses in the private sector involved days away from work, job transfer, or restricted duties at work, for a rate of 2.1 cases per 100 full-time workers. The rate of all reported nonfatal occupational injuries and illnesses in private industries was cut in half from 1989 (8.6 cases per 100 full-time workers) to 2007 (4.2 cases per 100) (Table 46 and Figure 11).

In 2007, there were nearly 36,000 new AIDS cases reported. Males 13 years of age and over accounted for 73% of all new cases. Black males made up 31% of all new cases, and black females accounted for 17% of all new cases (Table 48).

From 1990 to 2007, the incidence rate for chlamydia increased from 160 to 370 cases per 100,000 population, while the rate for gonorrhea and syphilis declined. In 2007, incident cases of acute viral hepatitis A and B were at historically low levels (Table 47).

In 2006–2007, 3% of the noninstitutionalized population 18 years of age and over was classified as having serious psychological distress. Adults living below the poverty level were more than four times as likely to report serious psychological distress as adults in families with an income at least twice the poverty level (7.2% compared with 1.6%, age-adjusted) (Table 58).

In 2005–2006, women 18 years of age and over (6.6%) were about 50% more likely than men (4.4%) to have current depression (Figure 12).

Between 1991 and 2007, the percentage of high school students who reported attempting suicide ranged between 7% and 9%, and the percentage who reported a suicide attempt that required medical attention ranged between 2% and 3% (Table 59).

In 2007, 59% of noninstitutionalized adults 65 years of age and over had basic actions difficulty (including movement or emotional difficulty or trouble seeing or hearing), and 34% had a complex activity limitation (such as work or self-care limitations) (Table 55).

In 2007, 10% of adults 18 years of age and over reported trouble seeing, even with glasses or contacts. Trouble seeing increased with age from 7% of adults 18–44 years of age to 18% of adults 75 years and over (Table 56).

In 2006–2007, speech problems, learning disabilities, and attention-deficit/hyperactivity disorder (ADHD or ADD) were the most frequently reported causes of activity limitation among children 5–11 years of age (Figure 13).

Arthritis and other musculoskeletal conditions were the leading causes of activity limitation among working-age adults 18–64 years of age in 2006–2007. Mental illness was the second most frequently mentioned condition causing activity limitation among adults 18–44 years of age and the third most frequently mentioned among adults 45–54 years of age (Figure 14).

## Health Care Utilization

Factors associated with the utilization of health care services include health behaviors, health status, health insurance coverage, health care resources, family income, and other demographic variables.

### Use of Medical Care Services

Use of inpatient hospital care remained relatively stable over the past decade, use of physician services increased slowly, and use of prescription drugs increased more rapidly.

In 2007, there were about 1.2 billion visits to physician offices, hospital outpatient departments, and hospital emergency departments. There were 994 million visits to physician offices, 89 million visits to hospital outpatient departments, and 117 million visits to hospital emergency departments (Table 91).

In 2006–2007, 7% of children under 6 years of age and 14% of children 6–17 years of age did not have a health care visit to a doctor’s office or a clinic in the past year (Table 79).

In 2007, 20% of adults 18 years of age and over had at least one emergency department visit in the past year, and 7% had two or more visits. Emergency department utilization was higher among persons with family income below 200% of poverty than for higher income persons (24%–30% compared with 18%) (Table 89).

Between 1997 and 2007, about two-thirds of persons 2 years of age and over had seen a dentist in the past year. Dental visit rates were higher among children 2–17 years of age than among adults, with three-quarters (73%–77%) of children having had a recent dental visit during this period (Table 93).

Between 1995 and 2006, nonfederal short-stay hospital discharge rates remained stable after declining sharply during the 1980s. During this period, average length of stay declined by about one-half a day, to 4.8 days in 2006 (Table 99).

In 1973–1974, the nursing home resident rate for the white population 65 years of age and over was more than twice that for the black population (61 compared with 28 per 1,000 population; age-adjusted). By 2004, the resident rate for the black population (50 per 1,000) exceeded that for the white population (34 per 1,000) (Table 105).

The percentage of the population with at least one prescription drug during the previous month increased from 39% in 1988–1994 to 47% in 2003–2006. During the same period, the percentage taking three or more prescription drugs increased from 12% to 21% (percentages are age-adjusted, Table 95).

In 2003–2006, 54% of adults 20 years of age and over reported taking a dietary supplement in the past month. The use of dietary supplements is higher among women than men, and reported use increases with age (Table 96).

In 2005–2006, 9% of adults had often or almost always used sleeping pills or medication to help them sleep in the past month (Figure 8).

### Use of Preventive Medical Care Services

Preventive health care improves the health of the Nation’s population. Children are protected from a number of childhood infectious diseases through routine vaccination. Vaccinations are an effective tool for protecting children and adults against influenza and other vaccine-preventable diseases. Mammography detects breast cancer at an earlier stage, when it is easier to treat. Pap smear screening detects infectious diseases and cervical cancer.

In 2007, 67% of children 19–35 months of age received the combined vaccination series of four doses of DTaP (diphtheria-tetanus-acellular pertussis) vaccine, three doses of polio vaccine, one dose of measles-containing vaccine, three doses of Hib (Haemophilus influenzae type b) vaccine, three doses of hepatitis B vaccine, one dose of varicella vaccine, and four or more doses of pneumococcal conjugate vaccine (Table 82).

Between 1989 and 2007, the percentage of noninstitutionalized adults 65 years of age and over who received an influenza vaccination in the past year more than doubled (from 30% to 67%). In 2007, 62% of those 65–74 years of age and 73% of those 75 years and over had an influenza vaccination in the past year (Figure 9 and Table 84).

Between 1989 and 2007, the percentage of noninstitutionalized adults 65 years of age and over who ever received a pneumococcal vaccination quadrupled (from 14% to 58%). In 2007, 52% of those 65–74 years of age and 64% of those 75 years and over ever had a pneumococcal vaccination (Figure 9 and Table 85).

The percentage of women 40 years of age and over who had a mammogram in the past 2 years more than doubled, increasing from 29% in 1987 to 70% in 1999. Between 1999 and 2008, the percentage of women 40 years and over who had a mammogram within the past 2 years decreased slightly, from 70% to 68% (Table 86 and Figure 26).

In 2008, 82% of women 18–44 years of age reported having a recent Pap smear (in the past 3 years). Recent Pap smear use remained higher among insured women 18–64 years of age than uninsured women (83% compared with 67% in 2008) (Table 87).

### Unmet Need for Medical Care

Because health care can be expensive, people without health insurance, or those who are underinsured, may not receive needed health care services or prescription drugs due to cost.

The percentage of adults 18–64 years of age who reported not getting needed medical care in the past year due to the cost increased from 6% to 8% between 1997 and 2007, and the percentage not getting needed prescription drugs increased from 6% to 10%, while the percentage who reported delaying medical care due to cost remained stable at 10% (Table 77).

In 2007, the percentage of persons who reported not receiving needed medical care because of cost varied by geographic region, from 4% in the Northeast to 7% in the South (Table 77).

In 2007, 20% of people under 65 years of age who were uninsured for up to a year did not receive needed medical care in the past 12 months due to the cost, compared with 3% of people covered by health insurance for the full year. Twenty-four percent of people under age 65 years who were uninsured for more than a year reported not receiving needed medical care due to cost (Table 77).

On January 1, 2006, Medicare Part D, which provides coverage for prescription medications for Medicare beneficiaries, went into effect. The percentage of adults 65 years of age and over with income below the poverty level who reported they did not get the prescription drugs they needed due to cost was 8%–9% in 2006 and 2007 (Table 77).

## Health Care Resources

Use of health care services is determined in part by the number of providers and institutions available to provide treatment. The ratio of physicians per population continues to increase, but the supply is not equally distributed across the country. The ratio of dentists per population is stable, but varies by state. The number of inpatient mental health beds continues to decline, and nursing home occupancy rates remain high.

In 2006, 43% of doctor visits were to specialty care physicians, up from 36% in 1990. During this period, the proportion of office-based doctor visits to general and family practice physicians decreased from 30% to 23% (Table 92).

Between 1995 and 2007, the number of physicians in patient care per 10,000 population increased 19%, to 25.3 per 10,000 population (Table 107).

Between 1993 and 2006, the number of dentists per 10,000 population remained stable at about 6.0. In 2006, the District of Columbia (10.5), Massachusetts (8.2), New Jersey (8.2), and Hawaii (8.1) had the most dentists per 10,000 population. The states with the fewest dentists per 10,000 population included Mississippi (4.0), Arkansas (4.1), and Alabama (4.4) (Table 110).

Between 1990 and 2007, the number of community hospital beds declined 14%, from about 927,000 to 801,000. Since 1990, the community hospital occupancy rate has remained between 63% and 67% (Table 115).

Between 1990 and 2004, the overall rate of inpatient mental health beds per 100,000 civilian population in the United States declined by 45%. The number of mental health beds per 100,000 population declined by 53% in state and county mental hospitals, by 48% in private psychiatric hospitals, and by 34% in nonfederal general hospital psychiatric services (Table 116).

In 2008, there were 1.7 million nursing home beds in 16,000 certified nursing homes. Between 1995 and 2008, nursing home bed occupancy was relatively stable at 82%–85%. Occupancy rates were 90% or higher in 14 states and the District of Columbia in 2008 (Table 119).

## Health Care Expenditures and Payors

### Health Care Expenditures

The United States spends more on health per capita than any other country, and U.S. health spending continues to increase. Spending increases are due to increased intensity and cost of services, and a higher volume of services, along with an aging population. Major payors for health care include private health insurers and public programs such as Medicaid and Medicare.

The United States spends a larger share of its gross domestic product (GDP) on health than does any other major industrialized country. In 2006, the United States devoted 15% of its GDP to health, compared with 11% in Switzerland, the country with the next highest share (Table 122).

In 2007, national health care expenditures in the United States totaled $2.2 trillion, a 6.1% increase from 2006. The average per capita expenditure on health in the United States was $7,400 in 2007 (Table 123).

Prescription drug expenditures increased 5% between 2006 and 2007, compared with a 9% increase between 2005 and 2006 (Table 126).

Expenditures for hospital care accounted for 31% of all national health expenditures in 2007. Physician and clinical services accounted for 21% of the total in 2007, prescription drugs for 10%, and nursing home care for 6% (Table 126).

In 2004, per capita personal health care expenditures increased with age, from $2,700 for children under 19 years of age to $25,700 for adults 85 years and over (Table 128).

### Health Care Payors

Medicaid is jointly funded by the federal and state governments to provide health care for certain groups of low-income persons. Medicare is funded by the federal government and provides health care coverage for most persons 65 years of age and over and disabled persons.

In 2007, 36% of personal health care expenditures were paid by private health insurance, consumers paid 14% out of pocket, and 45% were paid by public funds. The majority of public funds went toward Medicare and Medicaid expenditures (Figure 21 and Table 127).

In 2008, the Medicare program had 45 million enrollees and expenditures of $468 billion, up from $432 billion the previous year. Expenditures for the new Medicare drug program (Part D), introduced in 2006, were $49 billion in 2008 (Table 142).

Of the 35 million Medicare enrollees in the fee-for-service program in 2007, 18% were under 65 years of age, compared with 12% in 1994 (Table 143).

In 2006, children under 21 years of age accounted for 48% of Medicaid recipients but only 19% of expenditures. Aged, blind, and disabled persons accounted for 22% of recipients and 65% of expenditures (Table 145).

In 2007, the Children’s Health Insurance Program (CHIP) accounted for less than 1% of personal health care expenditures (Table 127).

### Health Insurance Coverage

Lack of health insurance coverage is a major barrier to obtaining most health care services. Out-of-pocket health care expenses may deter people from seeking health care services. People without health insurance are likely to face the highest costs, but the insured may also face substantial copayments, deductibles, and other out-of-pocket health care expenses.

In 2007, 17% of the population under 65 years of age had no health insurance coverage (public or private) at the time of interview. Between 1995 and 2007, this percentage fluctuated between 16% and 18% (Figure 19 and Table 140).

Among the under 65 population, persons with a family income less than 200% of the poverty level were 2.7 to 3 times more likely to be uninsured at the time of interview than persons in higher income families (Table 140).

In 2007, 9% of children under 18 years of age were uninsured at the time of interview. Between 2000 and 2007, among children in families with income just above the poverty level (100%–150% of poverty), the percentage uninsured dropped from 25% to 16%, whereas the percentage with coverage through Medicaid or CHIP increased from 35% to 55% (Tables 139 and 140).

In 2007, among persons under 65 years of age, almost one-third of Hispanic persons and almost two-fifths of American Indian and Alaska Native persons were uninsured at the time of interview, compared with fewer than one-fifth of those in other racial and ethnic groups (Table 140).

In 2007, one-third of people under 65 years of age with a family income below 200% of poverty were uninsured for at least part of the 12 months prior to interview, compared with 14% of people living in higher income families (Figure 20).

In 2007, 39% of people of Mexican origin were uninsured for at least part of the 12 months prior to interview, compared with 17% of non-Hispanic white people (Figure 20).

In 2005–2007, the percentage of persons who reported being uninsured for the entire year ranged from 8% in Hawaii and Massachusetts to 20% or more in Florida, New Mexico, and Texas (Table 150).

## Special Feature: Medical Technology

Technology continues to transform the medical care system as new and existing types of tests, imaging, procedures, devices, and machinery are increasingly utilized but at substantial cost.

Between 1996 and 2007, there was a more than three-fold increase in the number of visits per 100 population to physician offices and hospital outpatient departments during which MRI/CT/PET scans were ordered or provided, as well as a four-fold increase in advanced imaging ordered or provided during emergency department visits (Figure 25).

Between 1996 and 2006, the rate of hospital discharges with an angioplasty procedure without the insertion of a stent declined by 80% among persons 45 years of age and over. Since their introduction in 2003, drug-eluting coronary stents have rapidly displaced bare stents and were used in three-quarters of angioplasty discharges in 2006 (Figure 28).

Hospital discharges with at least one knee or hip replacement procedure among adults 45 years of age and over increased steadily from 1996 to 2006. Total hip replacement discharge rates increased by one-third, partial hip replacements increased by 60%, and total knee replacement discharge rates increased by 70% during that time period (Figure 27).

Ambulatory surgery procedure visits for cholecystectomy (gallbladder removal) increased more than 30%, from 16 visits per 10,000 population in 1996 to 21 per 10,000 in 2006, while inpatient cholecystectomy rates declined 19% during this period. By 2006, laparoscopic procedures accounted for three-quarters of inpatient cholecystectomies and virtually all ambulatory surgery cholecystectomies (Figure 29A and Figure 29B).

Between 1996 and 2006, ambulatory surgery visits per 10,000 population among adults for upper endoscopy (EGD) increased 90%, and lower endoscopy (colonoscopy) rates tripled (Figure 30).

All facilities that perform laboratory testing for the diagnosis, prevention, or treatment of disease or the assessment of human health are regulated under the Clinical Laboratory Improvement Amendments (CLIA). The percentage of CLIA laboratories that perform only waived or simple tests increased from 44% in 1993 to 64% in 2008 (Figure 24).

Between 1997 and 2006, the number of new kidney and liver transplantations per 1 million population increased 31% and 42%, respectively. In 2006, 16,700 kidney transplantations and 6,100 liver transplantations were performed (Figure 32).

The total number of assisted reproductive technology (ART) cycles initiated among women doubled from 1996 to 2006. During this period, the growth in ART cycles among women over 40 years of age increased at a faster rate on average (11% per year) than among women 35–40 years (8% per year) and those under 35 years (7% per year) (Figure 33).

Use of intensive care units in the last 6 months of life among Medicare decedents ranged from 23% of Medicare decedents in Vermont and North Dakota to 49% in New Jersey and Florida in 2005 (Figure 31).

Use of antidiabetic drugs among adults 45 years of age and over increased about 50% from 1988–1994 to 2003–2006. The use of statin drugs to control elevated serum cholesterol among adults 45 years and over increased almost 10-fold over this time period, from 2% to 22% (Figure 34).

HIV mortality fell sharply following the introduction of the HIV drug “cocktail” known as highly active antiretroviral therapy (HAART) in 1996. From 1995 to 1997, the death rate from HIV disease for males declined by two-thirds, from 27.3 deaths population in 1995 to 9.6 per 100,000 in 1997. Declines in HIV death rates also occurred for females and for all racial and ethnic groups (Figure 35).

Hospitalizations with respiratory intubation and mechanical ventilation, or coronary angioplasty, as the principal procedure contributed the most to overall hospital costs in 2006 (Figure 36).