# Acknowledgments

Overall responsibility for planning and coordinating the content of this edition of Health, United States rested with the Office of Analysis and Epidemiology, National Center for Health Statistics (NCHS), under the direction of Amy B. Bernstein, Diane M. Makuc, and Linda T. Bilheimer.

Production of Health, United States, 2009, highlights, trend tables, and appendixes was managed by Amy B. Bernstein, Sheila Franco, and Virginia M. Freid. Trend tables were prepared by Amy B. Bernstein, Mary Ann Bush, La-Tonya D. Curl, Catherine R. Duran, Sheila Franco, Virginia M. Freid, Tamyra C. Garcia, Ji-Eun Kim, Andrea P. MacKay, Patricia N. Pastor, Mitchell B. Pierre, Rebecca A. Placek, Cynthia A. Reuben, and Henry Xia, with assistance from Anita L. Powell and Ilene B. Rosen. Appendix II tables and the Index were assembled by Anita L. Powell. Production planning and coordination of the trend tables were managed by Rebecca A. Placek. Review and clearance books were assembled by Ilene B. Rosen. Administrative and word processing assistance was provided by Lillie C. Featherstone and Kimberly Heard.

Production of the Chartbook was managed by Virginia M. Freid. Data and analysis for specific charts were provided by Amy B. Bernstein, Margaret A. Cooke, Sheila Franco, Virginia M. Freid, Tamyra C. Garcia, Deborah D. Ingram, Ji-Eun Kim, Patricia N. Pastor, and Cynthia A. Reuben. Graphs were drafted by La-Tonya D. Curl, and data tables were prepared by Rebecca A. Placek. Technical assistance and programming were provided by Mary Ann Bush, Catherine R. Duran, Jeffrey Pearcy, Mitchell B. Pierre, and Henry Xia.

Publications management and editorial review were provided by Demarius V. Miller and Barbara J. Wassell, CDC/NCHM/Division of Creative Services, Writer-Editor Services Branch. Oversight review for publications and electronic products was provided by Linda Torian, Acting Director, Office of Information Services. The designer was Sarah Hinkle, CDC/NCHM/Division of Creative Services/Graphic Services Branch; production was done by Jacqueline M. Davis and Zung T. Le, CDC/NCHM/Division of Creative Services/Graphic Services Branch; and printing was managed by Patricia L. Wilson, CDC/OCOO/MASO.

Electronic access through the NCHS Internet site was provided by Christine J. Brown, Jacqueline M. Davis, Zung T. Le, Anthony Lipphardt, Demarius V. Miller, Anita L. Powell, Sharon L. Ramirez, Ilene B. Rosen, and Barbara J. Wassell.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Vladislav Beresovsky, Carol J. DeFrances, Marni J. Hall, Karen L. Lipkind, Maria F. Owings, Shaleah Patzer, Susan M. Schappert, Alex Schwartzman, and Ingrid Vassanelli; Division of Health Examination Statistics: Margaret D. Carroll, Lester R. Curtin, Bruce A. Dye, Cynthia L. Ogden, Kathy L. Radimer, Susan E. Schober, and Jaime J. Wilger; Division of Health Interview Statistics: Patricia F. Adams, Veronica Benson, Barbara Bloom, Robin A. Cohen, Margaret Lethbridge-Cejku, Eve Powell-Griner, Jeannine Schiller, and Charlotte A. Schoenborn; Division of Vital Statistics: Joyce C. Abma, Robert N. Anderson, Elizabeth Arias, Brady Hamilton, Melonie Heron, Donna L. Hoyert, Kenneth D. Kochanek, Joyce A. Martin, T. J. Mathews, Arialdi M. Miniño, William D. Mosher, Sherry L. Murphy, Michelle Osterman, and Stephanie V. Ventura; Office of Analysis and Epidemiology: Lara Akinbami, Barbara Altman, Li-Hui Chen, Lois Fingerhut, Deborah D. Ingram, Ellen Kramarow, Mitch Loeb, Susan Lukacs, Laura Pratt, Rashmi Tandon, Margaret Warner, and Julie Dawson Weeks; Office of the Center Director: Juan Rafael Albertorio-Diaz and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): Epidemiology Program Office: Samuel L. Groseclose, Michael Wodajo, and Patsy A. Hall; National Center for Chronic Disease Prevention and Health Promotion: Sonya Gamble, Laura Kann, Steve Kinchen, Shari L. Shanklin, Jeani Chang, and Valerie A. Jackson; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Michael Campsmith, Gail E. Scogin, Rachel S. Wynn, Annemarie Wasley, A. D. McNaghten, Peter Kilmarx, and Jill Wasserman; National Center for Immunization and Respiratory Diseases: Aaron Curns and James A. Singleton; National Center for Preparedness, Detection, and Control of Infectious Diseases: J. Rex Astles, Nancy L. Anderson, and Roberta B. Carey; National Institute for Occupational Safety and Health: Roger Rosa and John Sestito; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Roxanne Andrews, David Kashihara, Steven R. Machlin, and Marc W. Zodet; Centers for Medicare & Medicaid Services: Cathy A. Cowan, Frank Eppig, Denise Franz, David A. Gibson, Deborah W. Kidd, Maggie S. Murgolo, Olivia Nuccio, Joseph S. Regan, and Lekha Whittle; Health Resources and Services Administration: Monica Lin, Richard Laeng, Christopher J. McLaughlin, and Robert Walsh; National Institutes of Health: Moira O’Brien, Paul W. Eggars, Marie-Joseph Horner, Marsha Lopez, and Lynn A. G. Ries; Substance Abuse and Mental Health Services Administration: James Colliver; and by the following governmental and nongovernmental organizations: AcademyHealth: Michael Gluck; U.S. Census Bureau: Bernadette D. Proctor; Bureau of Justice Statistics: Paige Harrison, William Sabol, and Heather West; Bureau of Labor Statistics: Stella Cromartie, Kay Ford, Daniel Ginsburg, Diane Herz, Sara Kline, George Long, Stephen Pegula, and Elizabeth Rogers; Department of Veterans Affairs: William Kloiber, Pheakdey Lim, Dat Tran, and Henry Caplan; American Association of Colleges of Pharmacy: Jennifer M. Patton and Danielle Taylor; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Osteopathic Association: Wendy Bresler and Tom Levitan; American Dental Education Association: Jon D. Ruesch; Association of American Medical Colleges: Franc Slapar and Amber Sterling; Cowles Research Group: C. McKeen Cowles; The Guttmacher Institute: Stanely K. Henshaw and Rachel Jones; The Dartmouth Institute for Health Policy & Clinical Practice: Kristen K. Bronner and Elliott Fisher; NOVA Research Company: Shilpa Bengeri; and Social and Scientific Systems: Richard Jordan.