# Health Insurance and Expenditures

## Health Insurance at the Time of Interview

Between 1999 and 2007, the percentage of people under age 65 years with private health insurance declined, while enrollment in public coverage programs expanded.

Health insurance coverage is an important determinant of access to health care (1). Uninsured children and adults under 65 years of age are substantially less likely to have a usual source of health care or a recent health care visit than their insured counterparts (Tables 75–77 and 79–80). Uninsured people are more likely to forego needed health care because they cannot afford it (Table 77). The major source of coverage for persons under 65 years of age is private employer-sponsored group health insurance (Table 138). Private health insurance may also be purchased on an individual basis, but is generally more costly and tends to provide less adequate coverage than group health insurance. Public programs such as Medicaid and the Children’s Health Insurance Program (CHIP) provide coverage for many low-income children and adults (Table 139). Almost all adults 65 years of age and over are covered by the Medicare program, resulting in very few older adults without health insurance. Medicare enrollees may obtain additional private or public coverage to supplement their Medicare benefit package.

To estimate the percentage of people without coverage at a point in time, respondents to the National Health Interview Survey (NHIS) were asked whether they had health insurance at the time of their interview (Figure 19) (see Appendix II, Health insurance coverage). Between 1984 and 1994, private coverage declined among people under 65 years of age, while Medicaid enrollment and the percentage with no health insurance increased (Figure 19; Appendix II, Health insurance coverage). After rising to 73% in 1999, the percentage with private health insurance declined, reaching 67% in 2007. This decrease has been offset by an increase in the percentage with Medicaid or CHIP, resulting in little change in the percentage of persons under age 65 years who were uninsured.

Figure 19 Health insurance coverage at the time of interview among persons under 65 years of age: United States, 1984–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig19.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig19.ppt)

NOTES: Estimates for 2000–2002 were calculated using 2000-based sample weights and may differ from estimates in other reports that used 1990-based sample weights for 2000–2002 estimates. See data table for Figure 19.

SOURCE: CDC/NCHS, National Health Interview Survey.

In recent years, 16%–17% of people under 65 years of age had no health insurance at the time of their interview (Table 140), and 12% of people under 65 lacked insurance coverage for more than 12 months, making them chronically uninsured (data table for Figure 20). In 2007, cost was cited by more than one-half of these uninsured as the reason for their lack of coverage (2). Other reasons given were having lost a job or a change in employment (25%), Medicaid benefits stopped (11%), and ineligibility for family insurance coverage due to age or leaving school (8%).

Figure 20 Uninsured for at least part of the 12 months prior to interview among persons under 65 years of age, by length of time uninsured and selected characteristics: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig20.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig20.ppt)

* Estimates are considered unreliable. Data shown with an asterisk have a relative standard error of 20%–30%.

† Totals include percentage with unknown length of time uninsured.

NOTES: Persons of Hispanic origin may be of any race. Asian only race includes persons of Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See data table for Figure 20.

SOURCE: CDC/NCHS, National Health Interview Survey.

### References

1 Institute of Medicine, Committee on the Consequences of Uninsurance. (2001–2003). Series of reports: Coverage matters: Insurance and health care; Care without coverage; Health insurance is a family matter; A shared destiny: Community effects of uninsurance. Hidden costs, value lost: Uninsurance in America.
2 Adams PF, Barnes PM, Vickerie JL. (2008). Summary health statistics for the U.S. population: National Health Interview Survey, 2007. Vital Health Stat.

## Length of Time Without Health Insurance

People of Mexican origin are more likely than those in other racial or ethnic groups to be uninsured for more than 12 months.

Many people under age 65 years, particularly those with low income, do not have health insurance coverage consistently throughout the year. Reasons for discontinuities in coverage may include loss or change of employment and financial reversals, divorce, births and other changes in life circumstances, and migration between states. Chronically uninsured adults under age 65 experience greater declines in health status and die sooner than adults with continuous health insurance coverage because they are less likely to receive routine care, basic preventive services, and medications to manage conditions (1).

To estimate the percentage without coverage for different lengths of time, those covered by health insurance at the time of interview were asked whether there was any time during the 12 months prior to the interview when they did not have health insurance and those who were uninsured at the time of interview were asked how long it had been since they last had health coverage (Figure 20). In 2007, 21% of people under 65 years of age reported being uninsured for at least part of the 12 months prior to interview (Figure 20). Among those who reported any time without insurance coverage during the 12 months prior to interview, the majority reported being uninsured for more than 12 months. About 12% of people under age 65 reported being uninsured for more than 12 months, 8% reported being uninsured for any period up to 12 months, and 1% reported being uninsured and had missing data for the length of time they were uninsured (see data table for Figure 20).

Children under 18 years of age were less likely to be uninsured than were adults because low-income children are eligible for public programs such as CHIP designed specifically for them. The percentage of adults under age 65 without health insurance coverage decreased with age (Figure 20). In 2007, adults 18–34 years of age were more likely than adults 55–64 years of age to lack coverage for at least part of the 12 months prior to interview (33%–35%, compared with 13%) (Figure 20). About 18%–20% of adults 18–34 years of age lacked coverage for more than 12 months.

More than one-third of people with low family income (less than twice the poverty level) had no health insurance coverage for at least part of the 12 months prior to interview, compared with 14% of those with higher family income (Figure 20). More than one-fifth of people in these lower income families were uninsured for more than 12 months, compared with 7% of people in higher income families. People of Mexican origin were more likely than those in any other racial or ethnic group to be uninsured for at least part of the 12 months prior to interview. In 2007, 39% of Mexican-origin people lacked coverage for at least part of the 12 months prior to interview, with 29% lacking coverage for more than 12 months (Figure 20).

### Reference

1 Institute of Medicine. (2002). Care without coverage: Too little, too late.

## Personal Health Care Expenditures

In 2007, personal health care expenditures totaled $1.9 trillion.

In 2007, the United States spent $2.2 trillion (more than $7,400 per person) on health care, which accounted for 16% (up from 14% in 2000) of its gross domestic product (GDP)— a greater share than in any other developed country for which data are collected by the Organisation for Economic Co-operation and Development (Tables 122 and 123).

Personal health care expenditures—a component of national health expenditures that includes spending for hospital care, physician services, prescription drugs, nursing home care, dental care, and home health and other types of medical care—totaled $1.9 trillion in 2007 and accounted for 84% of national health expenditures. The remaining 16% was spent on program administration, government public health activities, noncommercial research, and structures and equipment (1) (Table 126).

Personal health care expenditures vary sharply by age. In 2004, estimates of per capita personal health care expenditures ranged from $2,700 among children under 19 years of age to $25,700 among persons 85 years of age and over (Table 128). Among persons 85 years of age and over, per capita expenditures were highest for nursing home and hospital care, at $8,700 and $7,900, respectively.

Private funds paid for slightly more than one-half (55%) of personal health care expenditures in 2007, with private health insurance accounting for 36% of total personal health expenditures in 2007 and out-of-pocket payments accounting for 14% (Figure 21). Public (government) funds paid for 45% of personal health care expenditures. Medicare paid for 22%, federal Medicaid and CHIP 9%, and state Medicaid and CHIP 7% of personal health care expenditures. Between 1990 and 2007, the share of personal health care expenditures paid out of pocket decreased from 22% to 14%, while the shares paid by private insurance and Medicare increased (Table 127 and also see Figure 22).

Figure 21 Personal health care expenditures, by source of funds and type of expenditures: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig21.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig21.ppt)

NOTES: Expenditures for Children’s Health Insurance Program (CHIP) and CHIP expansion are included with Medicaid. See data table for Figure 21.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Expenditure Accounts.

Figure 22 Personal health care expenditures, by source of funds: United States, 1990–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig22.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig22.ppt)

NOTE: See data table for Figure 22.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Expenditure Accounts.

In 2007, 37% of personal health care expenditures were for hospital care, 26% for physician services, 12% for prescription drugs, 7% for nursing home care, 5% for dental care, 3% for home health care, and the remaining 10% for other personal health care, including visits to nonphysician medical providers, medical supplies, and other health services (Figure 21). The share of total personal health care expenditures devoted to hospital care decreased from 41% in 1990 to 37% in 2007, while the share for prescription drug expenditures nearly doubled, from 7% to 12%, over the same period (Table 127).

### Reference

1 Hartman M, Martin A, McDonnell P, Catlin A. (2009). National health spending in 2007: Slower drug spending contributes to lowest rate of overall growth since 1998. Health Aff (Millwood).

## Personal Health Care Expenditures by Source of Funds

Personal health care expenditures paid by Medicaid have increased on average 9% per year, Medicare 8% per year, private health insurance 7% per year, and out-of-pocket payments 4% per year since 1990.

Personal health care expenditures include all spending for health services and supplies except program administration, the net cost of private insurance, and government public health activities. Between 1990 and 2007, total personal health expenditures tripled, increasing from $600 billion to $1.9 trillion (data table for Figure 22). During this period, per capita personal health care expenditures increased from about $2,400 to $6,200 (Table 127). If spending growth continues at the current rate, the Congressional Budget Office (CBO) estimates that total spending on health care (including nonpersonal expenditures such as construction and research) will rise from 16% of gross domestic product (GDP) in 2007 to 25% in 2025, 37% in 2050, and 49% in 2082 (1).

In 2007, slightly over one-half ($1 trillion) of personal health care expenditures were paid by private sources, including private health insurance, out-of-pocket payments by consumers, and philanthropy or other privately provided care. Public sources paid the remaining $850 billion, with the bulk being paid by the Medicare and Medicaid programs (Figure 21).

Although the percentage of people under age 65 years with private health insurance coverage has decreased from 76% in 1989 to 67% in 2007 (Figure 19), personal health care expenditures have increased rapidly in the private sector, particularly expenditures paid by private health insurance (Figure 22). Between 1990 and 1999, private health insurance expenditures increased, on average, 6.8% per year and increased at a faster rate from 2000 to 2007 (on average, 7.8% per year) (data table for Figure 22). The bulk of private expenditures are paid by private health insurance and increased from 55% in 1990 to 66% in 2007 (data table for Figure 22).

Aggregate out-of-pocket expenditures increased at a slower rate than private health insurance, increasing on average 3.4% per year between 1990 and 1999 (data table for Figure 22). Out-of-pocket expenditures grew more rapidly between 2000 and 2007, when the average annual increase in out-of-pocket expenditures was 4.9% (data table for Figure 22). The share of total personal health care expenditures paid out of pocket declined from 22% in 1990 to 14% in 2007 (data table for Figure 22).

Medicare and Medicaid expenditures have been increasing at a rapid rate, and the increase is a subject of much concern because CBO estimated that federal spending on Medicare (excluding beneficiaries’ premiums) and Medicaid will rise from 4% of GDP in 2007 to 7% in 2025, 12% in 2050, and 19% in 2082 (1). Between 1990 and 1999, Medicare expenditures increased on average 7.6% per year, (Figure 22 and Table 127). The Balanced Budget Act of 1997 included several provisions to control Medicare spending growth, which temporarily reduced Medicare expenditure growth. However, since 2000, Medicare expenditures have increased an average of 9.6% per year (data table for Figure 22). Recent growth in Medicare spending is attributable in part to Part D prescription drug coverage, which started in 2006, and to increased enrollment in Medicare Advantage plans since 2004 (2). Between 1990 and 2007, the share of personal health care expenditures paid by Medicare grew from 18% to 22% (data table for Figure 22).

Medicaid expenditures are shared by the federal and state governments, and the federal contribution varies by state (3). The Omnibus Reconciliation Act of 1987 (OBRA 87) expanded Medicaid coverage, including giving states the option of covering infants under the age of 1 and pregnant women in families with income up to 185% of the federal poverty level. The Children’s Health Insurance Program (CHIP), begun in 1998, extends public health care coverage to eligible uninsured low-income children. CHIP remains a small percentage (less than 1%) of total personal health care expenditures (Table 127). State Medicaid and CHIP expenditures increased, on average, 10.3% per year from 1990 to 1999 (data table for Figure 22). Growth in state Medicaid and CHIP expenditures has slowed somewhat since 2000, with an 8.0% average annual increase (data table for Figure 22). Federal Medicaid and CHIP expenditures increased an average of 10.8% per year from 1990 to 1999 and slowed to 6.6% from 2000 to 2007 (data table for Figure 22). Between 1990 and 2007, the share of personal health care expenditures paid by Medicaid (both state and federal programs) increased from 11% to 16% (data table for Figure 22).

Personal health expenditure increases are a product of the number of people in different public and private programs and plans, the volume of services provided, and the expenditure per service provided. Much of the increase in the Medicare and Medicaid program expenditures is due to increased enrollment and use of services, rather than increases in the amount paid per service, because these programs have regulated fee schedules or budgets that help control price increases (4). In contrast, enrollment in private health insurance plans has declined in recent years, yet expenditures continue to rise (2).

### References

1 Congressional Budget Office (CBO). (2007). The long-term outlook for health care spending. Pub no 3085.
2 Hartman M, Martin A, McDonnell P, Catlin A. (2009). National health spending in 2007: Slower drug spending contributes to lowest rate of overall growth since 1998. Health Aff (Millwood).
3 Office of the Actuary, Centers for Medicare & Medicaid Services (CMS). (2008). Actuarial report on the financial outlook for Medicaid.
4 Zuckerman S, McFeeters J. (2006). Recent growth in health expenditures.