# Executive Summary

Health, United States, 2009 is the 33rd annual report on the health status of the Nation, prepared by the Secretary of the Department of Health and Human Services for the President and the Congress. In a Chartbook and 150 detailed tables, the report provides an annual picture of the health of the entire United States. Trends are presented for health status and health care utilization, resources, and expenditures. This year’s report includes a special feature on medical technology. As advances in medical technology continue to transform the provision of health care and lengthen and improve quality of life, questions are increasingly raised about the appropriate and equitable use of this technology and how best to control its contribution to rising health care expenditures.

Monitoring the health of the American people is an essential step in making sound health policy and setting research and program priorities. Health, United States presents trends and current information on measures and determinants of the Nation’s health. It also identifies variations in health status, modifiable risk factors, and health care utilization among people by age, race and ethnicity, gender, education and income level, and geographic location. Given the increasing diversity of the Nation and the continuing changes in health care infrastructure, this is a challenging and critically important task.

In 2007, American men could expect to live 3.5 years longer—and women 1.6 years longer—than they did in 1990 (preliminary data; Table 24 and Figure 16). The gap in life expectancy between the black and white populations has narrowed, but it persists (Table 24 and Figure 16). Mortality from heart disease, stroke, and cancer has continued to decline in recent years, although mortality from chronic lower respiratory diseases and unintentional injuries has not (Tables 26, 32–34, and 37, and Figure 18). Infant mortality—a major component of overall life expectancy—declined through 2001 and has changed little since then (Table 17 and Figure 17). However, both life expectancy and infant mortality continue to lag behind levels in many other developed countries (Tables 22 and 23).

Longer life spans are generally considered desirable, particularly when healthy years of life are increased. But with an aging population and longer life expectancy come an increasing prevalence of chronic diseases and conditions associated with aging, including hypertension, diabetes, end-stage renal disease, and certain types of cancer (Tables 49–52 and 68), as well as Alzheimer’s disease and other dementias (Figure 15).

Although aging is associated with increased functional limitations and conditions that affect quality of life, those at younger ages may also face these issues. In 2007, 69 million adults 18 years of age and over had either basic actions difficulty (including movement or emotional difficulty or trouble seeing or hearing) or complex activity limitation (such as work or self-care limitations), an increase from about 61 million in 1997. One-quarter of adults 18–64 years of age had at least one basic actions difficulty or complex activity limitation in 2007, compared with 62% of adults 65 years of age and over (Table 55; for definitions, see Appendix II, Basic actions difficulty; Complex activity limitation). The percentage of adults 65 and over with fair or poor respondent-reported overall health status was 27% in 2007, down 2 percentage points for this older age group since 1991 (Table 57). About one-half of the adult population 75 years of age and over reported joint pain in 2007, similar to the percentage in 2002 (Table 54).

Infectious disease remains an important cause of morbidity and mortality. The number of new cases of many infectious diseases, such as measles and rubella, has decreased greatly as a result of vaccination and other prevention initiatives (Table 47 and Figure 9). However, incidence rates of some communicable diseases, including chlamydia, have increased (Table 47). In addition, newly recognized infectious agents have emerged and caused substantial public health concern and investment. These include influenza H1N1, SARS, H5N1 avian influenza, and some particularly virulent or drug-resistant bacterial strains, such as Methicillin-Resistant Staphylococcus aureus (MRSA) (1). Influenza and pneumonia remain major causes of death, particularly among persons 65 years of age and over, and HIV/AIDS continues to spread (Tables 29 and 48).

Of concern for all Americans is the high prevalence of people with risk factors such as tobacco use, high cholesterol, obesity, and insufficient exercise, which are associated with chronic diseases and conditions such as heart disease, cancer, diabetes, and hypertension. Declines in tobacco use have slowed in the past decade, and in 2007 22% of men and 17% of women were cigarette smokers (Table 60). Cholesterol levels have been dropping, in particular for the oldest adults, due in large part to increased use of drug therapy (Figure 34, and Tables 69 and 94). Obesity rates do not appear to be increasing as rapidly as they did in past decades but remain high, with more than one-third of adults 20 years of age and over classified as obese in 2005–2006 (Tables 67 and 72, and Figure 7). Obesity rates among women continue to vary by race and ethnicity; 53% of non-Hispanic black women 20 years of age and over were obese in 2003–2006, compared with 42% of women of Mexican origin and 32% of non-Hispanic white women (Table 72, age-adjusted). The percentage of adults 18 years of age and over who engaged in regular leisure-time physical activity has not increased in the past decade (Table 71).

Americans use vast quantities of health care services. The percentage of the population with at least one hospital stay in the past 12 months has remained constant since 1997 at about 7%–8% (Table 98). In 2006, that translated to about 35 million hospital discharges (Table 100). In 2007, there were 1.2 billion visits to physician offices, hospital outpatient departments, and emergency departments (Table 91). The average number of visits each year to physician offices remained steady, at about three per person, between 1995 and 2007 (Table 91). In 2003–2006, almost one-half (47%) of Americans interviewed had at least one drug prescribed in the previous month, compared with 39% in 1988–1994 (Table 95).

Preventive health care services improve health by protecting against disease, lessening its impact, or detecting disease at an early stage when it is easier to treat. Although Americans use many types of clinical preventive services, utilization remains suboptimal for some services. In 2007, only 67% of children 19–35 months of age received a combined vaccination series protecting them against seven childhood infectious diseases (Table 82). One-half of adults 50 years of age and over received an influenza vaccination in 2007, similar to the percentage in 2000 (Table 84 and Figure 9). Nearly 60% of adults 65 years of age and over ever had a pneumococcal vaccination in 2007, a slight increase over the level in 2000 (Table 85 and Figure 9). In 2008, two-thirds of women 40 years of age and over had a mammogram in the past 2 years (Table 86 and Figure 26). Disparities by poverty level remain in the use of pneumococcal vaccination, mammography, and Pap smears (Tables 85–87).

Although most Americans have access to the health care services they need, in 2007 8% of adults 18–64 years of age reported that they did not get needed medical care due to cost—an increase from 6% in 1997 (Table 77). Ten percent of this age group reported that they did not get needed prescription drugs during the 12 months prior to the interview, also due to cost, compared with 6% in 1997 (Table 77).

Access to health care is strongly associated with health insurance coverage. People with no health insurance are less likely to receive some needed health services than people with insurance (Table 77). About 43 million people—16.6% of Americans under 65 years of age—did not have health insurance coverage at the time they were interviewed in 2007 (Table 140). This represents a small decrease from 1997, when an estimated 17.5% of persons under age 65 were uninsured. Hispanic persons remain substantially more likely to be uninsured than persons in other racial and ethnic groups (Table 140 and Figure 20). The percentage of people under age 65 with Medicaid or Children’s Health Insurance Program (CHIP) coverage increased from 10% in 1997 to 14% in 2007, primarily due to increased Medicaid or CHIP coverage among children (Table 139), whereas the percentage of persons under age 65 with private insurance coverage decreased from 71% to 67% during that time period (Table 137).

Health care technologies, facilities, equipment, and provider specialties have changed over recent decades. Until the mid-20th century, general hospitals and primary care physicians were the major providers of health care. There are now more physician specialties and subspecialties, and more specialized health care facilities, including imaging centers, outpatient surgical centers, and dialysis centers (Tables 108, 120, and 121). More procedures are being furnished on an outpatient basis (Table 104). The number of physicians per capita has been increasing, but physicians are not distributed equally across the Nation (Table 107). Projections indicate that there may be a continuing shortage of the nurses, pharmacists, and other health professionals needed to care for our aging population and handle the increasing use of technologically complex equipment and procedures (2,3).

The United States spends more on health per capita than any other country, and health spending continues to increase (Tables 122 and 123). In 2007, national health expenditures in the United States totaled $2.2 trillion—a 6% increase from 2006 (Table 123). This represents 16% of the total U.S. gross domestic product (GDP); in 1980, national health expenditures were 9% of the GDP (Table 123). Hospital spending, which accounts for 31% of national health expenditures, increased 7% in 2007 (Table 126). Spending for prescription drugs accounted for 10% of national health expenditures in 2007. This spending increased only 5% in 2007—the smallest increase in many decades (Table 126).

This year, Health, United States includes a special feature focusing on advances in medical technology, which have improved our ability to monitor, prevent, diagnose, control, and cure a growing number of health conditions. Medical technology can be defined as the application of science to develop solutions to health problems or issues, such as the prevention or delay of onset of disease or the promotion and monitoring of good health (4,5). Examples include medical and surgical procedures (angioplasty, joint replacements, organ transplants), diagnostic tests (laboratory tests, biopsies, imaging), drugs (biologic agents, pharmaceuticals, vaccines), medical devices (implantable defibrillators, stents, prosthetics), and new support systems (electronic medical records and telemedicine). Figure 23 presents selected key health care technologies developed in the past two centuries that have greatly influenced medical practice and health care outcomes.

As some types of medical technology become easier to use and less expensive—and as equipment becomes more transportable and recovery times for procedures are reduced—even complex technologies can diffuse out of hospitals and institutional settings and into ambulatory surgery centers, provider offices, outpatient facilities, imaging centers, and patients’ homes, making the technologies more accessible. For example, laparoscopic surgical techniques have made cholecystectomy (gallbladder removal) available to high-risk, reluctant, or mildly symptomatic patients and have helped shift the procedure to outpatient care (Figure 29A and Figure 29B). Better prosthetic materials and improvements in surgical techniques may help explain why the rate of hospital discharges for total knee replacement procedures among persons 45 years of age and over increased 70% from 1996 to 2006 (Figure 27). Advanced imaging has improved the ability to diagnose and treat conditions more effectively, and utilization rates have increased substantially over the past decade (Figure 25). New medical devices such as drug-eluting stents have changed treatment for blocked arteries, and rates of stent procedures have also increased over the past 10 years (Figure 28).

Access to technologies differs among subgroups of the population in need, as well as by geography. For example, gender, racial, and ethnic differences in HIV mortality persist, even with the advent of highly active antiretroviral therapy (HAART) (Figure 35). In 2008, Hispanic women 40 years of age and over were less likely to have received a mammogram in the past 2 years than non-Hispanic white or non-Hispanic black women (Figure 26). Among Medicare beneficiaries, use of ICU/CCU care in the last 6 months of life varied considerably across the states (Figure 31).

New technology—and new uses for existing technology—can improve the length and quality of life. However, questions remain about how much improvement is possible when resources are scarce and costs continue to increase (5,6). In addition, there is concern about whether target populations are being appropriately and equitably served.

To improve the health of all Americans, it is critical to continue collecting data on all components of health; documenting trends in risk factors, health status, and access to and utilization of health care services; and disseminating reliable and accurate information about the health of our population. Equally important is gaining an understanding of the health care needs and utilization patterns of population subgroups. Such insights will enable policymakers to set program priorities and allocate target resources most effectively. The Health, United States, 2009 highlights that follow summarize the latest findings gathered from public and private data sources to help the Department of Health and Human Services, the President, and the Congress carry out their mission of monitoring and improving the health of the Nation.

## References

1 Lashley FR. (2006). Emerging infectious diseases at the beginning of the 21st century. Online J Issues Nurs.
2 Kuehn BM. (2007). No end in sight to nursing shortage: Bottleneck at nursing schools a key factor. JAMA.
3 Walton SM, Knapp KK, Miller L, Schumock GT. (2007). Examination of state-level changes in the pharmacist labor market using Census data. J Am Pharm Assoc.
4 De Miranda MA, Doggett AM, Evans JT. (2005). Medical technology: Contexts and content in science and technology.
5 (2007). Snapshots: Health care costs. How changes in medical technology affect health care costs [online].
6 Garber AM, Fuchs V. (2003). Medical innovation: Promises and pitfalls [online].