# Data Tables for Figures 1–36

Data table for Figures 1A and 1B Total population, by age: United States, 1980–2050

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig01.xls) Click here for powerpoint slide 1A (http://www.cdc.gov/nchs/ppt/hus/HUS09fig01a.ppt) Click here for powerpoint slide 1B (http://www.cdc.gov/nchs/ppt/hus/HUS09fig01b.ppt)

NOTE: See Chartbook Figure 1A and Figure 1B for Table 1

Year | All ages | Under 18 years | 18–44 years | 45–64 years | 65–74 years | 75 years and over
| Number
1980 | 226,545,805 | 63,754,960 | 92,738,756 | 44,502,662 | 15,580,605 | 9,968,822
1990 | 248,709,873 | 63,923,717 | 107,537,959 | 46,169,302 | 18,045,495 | 13,033,400
2000 | 281,421,906 | 72,293,812 | 112,183,705 | 61,952,636 | 18,390,986 | 16,600,767
2007 | 301,621,157 | 73,901,733 | 113,244,630 | 76,586,836 | 19,352,149 | 18,535,809
2010 | 310,232,863 | 75,217,106 | 113,807,468 | 80,979,577 | 21,462,599 | 18,766,113
2020 | 341,386,665 | 81,685,129 | 120,540,869 | 84,356,197 | 32,312,186 | 22,492,284
2030 | 373,503,674 | 87,815,218 | 129,300,761 | 84,295,780 | 38,784,325 | 33,307,590
2040 | 405,655,295 | 93,986,401 | 138,430,208 | 92,000,295 | 36,895,223 | 44,343,168
2050 | 439,010,253 | 101,573,687 | 150,399,841 | 98,489,752 | 40,112,637 | 48,434,336
| Percent distribution
1980 | 100.0 | 28.1 | 40.9 | 19.6 | 6.9 | 4.4
1990 | 100.0 | 25.7 | 43.2 | 18.6 | 7.3 | 5.2
2000 | 100.0 | 25.7 | 39.9 | 22.0 | 6.5 | 5.9
2007 | 100.0 | 24.5 | 37.5 | 25.4 | 6.4 | 6.1
2010 | 100.0 | 24.2 | 36.7 | 26.1 | 6.9 | 6.0
2020 | 100.0 | 23.9 | 35.3 | 24.7 | 9.5 | 6.6
2030 | 100.0 | 23.5 | 34.6 | 22.6 | 10.4 | 8.9
2040 | 100.0 | 23.2 | 34.1 | 22.7 | 9.1 | 10.9
2050 | 100.0 | 23.1 | 34.3 | 22.4 | 9.1 | 11.0

NOTES: Data are for the resident population. Data for 1950 exclude Alaska and Hawaii. Data for 2010–2050 are projected. (See Appendix II, Population.)

SOURCES: U.S. Bureau of the Census: 1950 Nonwhite population by race. Special report P–E, No. 3B. Washington, DC: U.S. Government Printing Office, 1951 [data for 1950]; U.S. Census of Population: 1960, Number of inhabitants, PC(1)–A1, United States Summary, 1964 [data for 1960]; Number of inhabitants, final report PC(1)–A1, United States Summary, 1971 [data for 1970]; 1980 Census of Population, General population characteristics, United States Summary (PC80–1–B1) [data for 1980]; 1990 Census of Population, General population characteristics, United States Summary (CP–1–1) [data for 1990]. U.S. Census Bureau: Annual estimates of the population by sex and five-year age groups for the United States: April 1, 2000, to July 1, 2007 (NC–EST2007–01), available from: http://www.census.gov/popest/national/asrh/NC-EST2007-sa.html [data for 2000 and 2007]; National population projections by single year of age, sex, race, and Hispanic origin, 2008. Detail file available from: http://www.census.gov/population/www/projections/downloadablefiles.html [data for projections].

Data table for Figure 2 Population in selected race and Hispanic origin groups, by age: United States, 1980–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig02.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig02.ppt)

NOTE: See Chartbook Figure for Table 2

| All ages | | | | Under 18 years
Race and Hispanic origin | 1980 | 1990 | 2000 | 2008 | 1980 | 1990 | 2000 | 2008
| Percent distribution
Total | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0
Hispanic or Latino | 6.4 | 9.0 | 12.5 | 15.4 | 8.8 | 12.2 | 17.1 | 21.4
Not Hispanic or Latino:
White | 79.9 | 75.7 | 69.5 | 65.5 | 74.2 | 68.9 | 61.3 | 56.4
Black or African American | 11.5 | 11.8 | 12.2 | 12.3 | 14.5 | 14.7 | 14.9 | 14.5
American Indian or Alaska Native | 0.6 | 0.7 | 0.7 | 0.8 | 0.8 | 1.0 | 1.0 | 0.9
Asian | 1.6 | 2.8 | 3.7 | 4.4 | 1.7 | 3.1 | 3.5 | 4.1
Native Hawaiian or Other Pacific Islander | . . . | . . . | 0.1 | 0.1 | . . . | . . . | 0.2 | 0.1
2 or more races | . . . | . . . | 1.2 | 1.4 | . . . | . . . | 2.2 | 2.6
| 18 years and over
Race and Hispanic origin | 1980 | | 1990 | | 2000 | | 2008
| Percent distribution
Total. | 100.0 | | 100.0 | | 100.0 | | 100.0
Hispanic or Latino | 5.5 | | 7.9 | | 11.0 | | 13.5
Not Hispanic or Latino:
White | 82.1 | | 78.0 | | 72.3 | | 68.5
Black or African American | 10.4 | | 10.8 | | 11.3 | | 11.6
American Indian or Alaska Native | 0.5 | | 0.6 | | 0.7 | | 0.7
Asian | 1.5 | | 2.7 | | 3.8 | | 4.5
Native Hawaiian or Other Pacific Islander | . . . | | . . . | | 0.1 | | 0.1
2 or more races | . . . | | . . . | | 0.9 | | 1.0
| 18–44 years | | | | 45–64 years
Race and Hispanic origin | 1980 | 1990 | 2000 | 2008 | 1980 | 1990 | 2000 | 2008
| Percent distribution
Total | . . . | 100.0 | 100.0 | 100.0 | . . . | 100.0 | 100.0 | 100.0
Hispanic or Latino. | 6.8 | 9.8 | 14.6 | 18.2 | 4.4 | 6.2 | 7.8 | 10.1
Not Hispanic or Latino.
White | 79.2 | 74.2 | 66.2 | 61.2 | 84.6 | 81.1 | 76.8 | 73.2
Black or African American | 11.5 | 12.1 | 12.8 | 13.2 | 9.3 | 9.7 | 10.3 | 10.9
American Indian or Alaska Native | . . . | 0.7 | 0.8 | 0.8 | . . . | 0.6 | 0.6 | 0.7
Asian | . . . | 3.2 | 4.3 | 5.2 | . . . | 2.5 | 3.5 | 4.2
Native Hawaiian or Other Pacific Islander | . . . | . . . | 0.2 | 0.2 | . . . | . . . | 0.1 | 0.1
2 or more races | . . . | . . . | 1.1 | 1.3 | . . . | . . . | 0.8 | 0.8
| 65–74 years | | | | 75 years and over
Race and Hispanic origin | 1980 | 1990 | 2000 | 2008 | 1980 | 1990 | 2000 | 2008
| Percent distribution
Total. | . . . | 100.0 | 100.0 | 100.0 | . . . | 100.0 | 100.0 | 100.0
Hispanic or Latino | 2.9 | 4.0 | 5.9 | 7.5 | 2.5 | 3.3 | 4.0 | 6.1
Not Hispanic or Latino:
White | 87.4 | 85.9 | 81.7 | 78.5 | 89.1 | 87.8 | 86.2 | 82.4
Black or African American | 8.5 | 8.1 | 8.7 | 9.0 | 7.5 | 7.5 | 7.2 | 7.5
American Indian or Alaska Native | . . . | 0.4 | 0.4 | 0.6 | . . . | 0.3 | 0.3 | 0.4
Asian | . . . | 1.6 | 2.7 | 3.7 | . . . | 1.1 | 1.9 | 3.0
Native Hawaiian or Other Pacific Islander | . . . | . . . | 0.1 | 0.1 | . . . | . . . | 0.0 | 0.1
2 or more races | . . . | . . . | 0.5 | 0.7 | . . . | . . . | 0.4 | 0.5

0.0 Quantity more than zero but less than 0.05.

. . . Category not applicable.

NOTES: Populations for age groups may not sum to 100% due to rounding. Data are for the resident population. Persons of Hispanic origin may be of any race. Race data for 2000 and beyond are not directly comparable with data for 1980 and 1990. Individuals could report only one race in 1980 and 1990 and more than one race in 2000 and beyond. Persons who selected only one race in 2000 and beyond are in single-race categories; persons who selected more than one race in 2000 and beyond are shown as having 2 or more races and are not included in single-race categories. In 1980 and 1990, the Asian category included Asian and Native Hawaiian or Other Pacific Islander; in 2000 and beyond, this category includes only Asian. Data not available for American Indian or Alaska Native and Asian populations by selected age groups in 1980. (See Appendix II, Hispanic origin; Race.)

SOURCES: U.S. Census Bureau: 1980 census of population and housing county population, by age, sex, race, and Spanish origin (Preliminary OMB-consistent modified race) Technical Documentation. D1–D80–CTYP–14–TECHP. Washington, DC: U.S. Government Printing Office, 1982; Monthly postcensal resident populations, from April 1, 1990, to July 1, 2000, by age, sex, race, and Hispanic origin. Available from: http://www.census.gov/popest/archives/1990s/nat_monthly_resident.html [for April 1, 1990, and November 1, 2000]; Monthly postcensal resident populations, from July 1, 2000, to July 1, 2008, by age, sex, race, and Hispanic origin. Available from: http://www.census.gov/popest/national/asrh/2007-nat-res.html [for April 1, 2000 and July 1, 2008].

Data table for Figure 3 Population of living veterans, by service-connected disability status and period of service: United States, selected years, 1970–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig03.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig03.ppt)

NOTE: See Chartbook Figure for Table 3

Service-connected disability (SCD) status | 1970 | 1980 | 1990 | 2000 | 2007
| Number in millions
Receiving compensation for SCD | 2.1 | 2.3 | 2.2 | 2.3 | 2.8
Not receiving compensation for SCD | 25.6 | 27.8 | 25.3 | 24.1 | 21.0
| Percent
Receiving compensation for SCD | 7.6 | 7.6 | 8.0 | 8.7 | 11.8
Earliest period of service | 2007
| Number in millions
Total | 23.8
Period of service:
World War II | 2.9
Korean conflict | 2.7
Vietnam era | 7.6
Gulf War (service from 8/2/1990 to present) | 4.6
Peacetime | 6.1

NOTES: Includes data on living veterans from the 50 states, the District of Columbia, Puerto Rico, and outlying U.S. areas. Data only include persons who served on active duty. Data do not include living veterans who served prior to World War II. Period-of-service data are based on data from U.S. Department of Veterans Affairs. Veterans are classified by their earliest period of service. Gulf War service is from August 2, 1990, to present and does not reflect deployment or service location. SCD status is based on the number of living veterans qualified as having an SCD incurred or aggravated while on active duty and receiving financial compensation for that SCD. SCD status data are from the Statistical Abstracts of the United States, U.S. Census Bureau, based on data from U.S. Department of Veterans Affairs. Data as of September 30 for 1980 to present. Data as of June 30 for 1970. Percents are based on numbers in thousands. For more information on data sources, see the Technical Notes.

SOURCES: U.S. Department of Veterans Affairs and U.S. Census Bureau.

Data table for Figure 4 Poverty by age: United States, 1966–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig04.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig04.ppt)

NOTE: See Chartbook Figure for Table 4

Year | All ages | Under 18 years | 18–64 years | 65 years and over
| Percent of persons with family income below the poverty level
1966 | 14.7 | 17.6 | 10.5 | 28.5
1967 | 14.2 | 16.6 | 10.0 | 29.5
1968 | 12.8 | 15.6 | 9.0 | 25.0
1969 | 12.1 | 14.0 | 8.7 | 25.3
1970 | 12.6 | 15.1 | 9.0 | 24.6
1971 | 12.5 | 15.3 | 9.3 | 21.6
1972 | 11.9 | 15.1 | 8.8 | 18.6
1973 | 11.1 | 14.4 | 8.3 | 16.3
1974 | 11.2 | 15.4 | 8.3 | 14.6
1975 | 12.3 | 17.1 | 9.2 | 15.3
1976 | 11.8 | 16.0 | 9.0 | 15.0
1977 | 11.6 | 16.2 | 8.8 | 14.1
1978 | 11.4 | 15.9 | 8.7 | 14.0
1979 | 11.7 | 16.4 | 8.9 | 15.2
1980 | 13.0 | 18.3 | 10.1 | 15.7
1981 | 14.0 | 20.0 | 11.1 | 15.3
1982 | 15.0 | 21.9 | 12.0 | 14.6
1983 | 15.2 | 22.3 | 12.4 | 13.8
1984 | 14.4 | 21.5 | 11.7 | 12.4
1985 | 14.0 | 20.7 | 11.3 | 12.6
1986 | 13.6 | 20.5 | 10.8 | 12.4
1987 | 13.4 | 20.3 | 10.6 | 12.5
1988 | 13.0 | 19.5 | 10.5 | 12.0
1989 | 12.8 | 19.6 | 10.2 | 11.4
1990 | 13.5 | 20.6 | 10.7 | 12.2
1991 | 14.2 | 21.8 | 11.4 | 12.4
1992 | 14.8 | 22.3 | 11.9 | 12.9
1993 | 15.1 | 22.7 | 12.4 | 12.2
1994 | 14.5 | 21.8 | 11.9 | 11.7
1995 | 13.8 | 20.8 | 11.4 | 10.5
1996 | 13.7 | 20.5 | 11.4 | 10.8
1997 | 13.3 | 19.9 | 10.9 | 10.5
1998 | 12.7 | 18.9 | 10.5 | 10.5
1999 | 11.9 | 17.1 | 10.1 | 9.7
2000 | 11.3 | 16.2 | 9.6 | 9.9
2001 | 11.7 | 16.3 | 10.1 | 10.1
2002 | 12.1 | 16.7 | 10.6 | 10.4
2003 | 12.5 | 17.6 | 10.8 | 10.2
2004 | 12.7 | 17.8 | 11.3 | 9.8
2005 | 12.6 | 17.6 | 11.1 | 10.1
2006 | 12.3 | 17.4 | 10.8 | 9.4
2007 | 12.5 | 18.0 | 10.9 | 9.7

NOTES: Data are for the civilian noninstitutionalized population. Poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. (See Appendix II, Poverty. Also see Table 3.)

SOURCES: U.S. Census Bureau, Current Population Survey, 1967–2008 Annual Social and Economic Supplements. DeNavas-Walt C, Proctor BD, Smith JC. Income, poverty, and health insurance coverage in the United States: 2007. U.S. Census Bureau, Current Population Reports, P60–235. Washington, DC: U.S. Government Printing Office; 2008. Available from: http://www.census.gov/prod/2008pubs/p60-235.pdf.

Data table for Figure 5 Low income by age, race and Hispanic origin: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig05.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig05.ppt)

NOTE: See Chartbook Figure for Table 5

| Percent of poverty level
Characteristic | Below 100% | 100%–less than 200% | Below 100% | 100%–less than 200%
| Percent | | Number in millions
All ages
All races and origins | 12.5 | 18.0 | 37.3 | 53.8
Hispanic or Latino | 21.5 | 29.1 | 9.9 | 13.4
Black or African American only | 24.5 | 23.0 | 9.2 | 8.6
Asian only | 10.2 | 14.8 | 1.3 | 2.0
White only, not Hispanic or Latino | 8.2 | 14.7 | 16.0 | 28.8
Under 18 years
All races and origins | 18.0 | 21.2 | 13.3 | 15.7
Hispanic or Latino | 28.6 | 32.2 | 4.5 | 5.0
Black or African American only | 34.5 | 26.1 | 3.9 | 2.9
Asian only | 12.5 | 16.7 | 0.4 | 0.5
White only, not Hispanic or Latino | 10.1 | 16.0 | 4.3 | 6.7
18–64 years
All races and origins | 10.9 | 15.1 | 20.4 | 28.4
Hispanic or Latino | 17.9 | 26.9 | 5.0 | 7.5
Black or African American only. | 19.8 | 20.4 | 4.6 | 4.7
Asian only | 9.2 | 13.3 | 0.8 | 1.2
White only, not Hispanic or Latino | 7.7 | 11.7 | 9.6 | 14.6
65 years and over
All races and origins | 9.7 | 26.4 | 3.6 | 9.7
Hispanic or Latino | 17.1 | 34.2 | 0.4 | 0.9
Black or African American only. | 23.2 | 30.8 | 0.7 | 1.0
Asian only | 11.3 | 20.9 | 0.1 | 0.3
White only, not Hispanic or Latino | 7.4 | 25.4 | 2.2 | 7.5

NOTES: Data are for the civilian noninstitutionalized population. Persons of Hispanic origin may be of any race. Black and Asian races include persons of both Hispanic and non-Hispanic origin. Populations for age groups may not sum to the total due to rounding. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. (See Appendix II, Hispanic origin; Poverty; Race. Also see Table 3.)

SOURCES: U.S. Census Bureau, Current Population Survey, Annual Social and Economic Supplements 1967–2008. DeNavas-Walt C, Proctor BD, and Smith JC. Income, poverty, and health insurance coverage in the United States: 2007. U.S. Census Bureau, Current Population Reports, P60–235. Washington, DC: U.S. Government Printing Office; 2008. Available from: http://www.census.gov/prod/2008pubs/p60-235.pdf. Age and sex of all people, family members, and unrelated individuals iterated by income-to-poverty ratio and race: 2007. Available from: http://pubdb3.census.gov/macro/032008/pov/new01_200_01.htm.

Data table for Figure 6 Cigarette smoking among men, women, and high school students: United States, 1965–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig06.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig06.ppt)

NOTE: See Chartbook Figure for Table 6

| Current smoker | | | | Former smoker | | | | Never smoker
| Men | | Women | | Men | | Women | | Men | | Women | | High school students
Year | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE
1965 | 51.2 | 0.3 | 33.7 | 0.3 | 20.2 | 0.2 | 8.0 | 0.2 | 28.6 | 0.3 | 58.3 | 0.4 | - - - | - - -
1974 | 42.8 | 0.5 | 32.2 | 0.4 | 29.1 | 0.5 | 13.0 | 0.3 | 28.1 | 0.5 | 54.8 | 0.5 | - - - | - - -
1979 | 37.0 | 0.5 | 30.1 | 0.5 | 30.6 | 0.5 | 15.4 | 0.4 | 32.4 | 0.5 | 54.5 | 0.5 | - - - | - - -
1983 | 34.8 | 0.6 | 29.4 | 0.4 | 30.9 | 0.5 | 16.3 | 0.4 | 34.4 | 0.5 | 54.2 | 0.5 | - - - | - - -
1985 | 32.2 | 0.5 | 27.9 | 0.4 | 33.5 | 0.5 | 18.6 | 0.4 | 34.3 | 0.5 | 53.5 | 0.5 | - - - | - - -
1987 | 30.9 | 0.4 | 26.5 | 0.4 | 31.3 | 0.4 | 17.8 | 0.3 | 37.8 | 0.4 | 55.6 | 0.4 | - - - | - - -
1988 | 30.3 | 0.4 | 25.7 | 0.3 | 32.0 | 0.4 | 19.0 | 0.3 | 37.7 | 0.4 | 55.3 | 0.4 | - - - | - - -
1989 | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - -
1990 | 28.0 | 0.4 | 22.9 | 0.3 | 32.4 | 0.4 | 19.9 | 0.3 | 39.6 | 0.4 | 57.3 | 0.4 | - - - | - - -
1991 | 27.6 | 0.4 | 23.5 | 0.3 | 31.9 | 0.4 | 19.3 | 0.3 | 40.5 | 0.4 | 57.1 | 0.4 | 27.5 | 1.4
1992 | 28.1 | 0.5 | 24.6 | 0.5 | 30.9 | 0.5 | 18.8 | 0.4 | 41.0 | 0.5 | 56.6 | 0.6 | - - - | - - -
1993 | 27.3 | 0.6 | 22.6 | 0.4 | 31.6 | 0.5 | 19.9 | 0.4 | 41.1 | 0.6 | 57.5 | 0.5 | 30.5 | 1.0
1994 | 27.6 | 0.5 | 23.1 | 0.5 | 31.5 | 0.5 | 20.3 | 0.4 | 40.9 | 0.6 | 56.6 | 0.5 | - - - | - - -
1995 | 26.5 | 0.6 | 22.7 | 0.5 | 29.2 | 0.6 | 19.6 | 0.5 | 44.3 | 0.7 | 57.7 | 0.6 | 34.8 | 1.2
1996 | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - -
1997 | 27.1 | 0.4 | 22.2 | 0.4 | 28.5 | 0.4 | 19.1 | 0.3 | 44.5 | 0.5 | 58.7 | 0.4 | 36.4 | 1.1
1998 | 25.9 | 0.4 | 22.1 | 0.4 | 28.8 | 0.4 | 18.8 | 0.3 | 45.3 | 0.5 | 59.2 | 0.5 | - - - | - - -
1999 | 25.2 | 0.5 | 21.6 | 0.4 | 28.5 | 0.4 | 19.1 | 0.4 | 46.3 | 0.5 | 59.3 | 0.4 | 34.8 | 1.3
2000 | 25.2 | 0.4 | 21.1 | 0.4 | 26.9 | 0.4 | 18.8 | 0.4 | 48.0 | 0.5 | 60.1 | 0.4 | - - - | - - -
2001 | 24.6 | 0.4 | 20.7 | 0.4 | 27.4 | 0.4 | 18.1 | 0.3 | 48.0 | 0.5 | 61.2 | 0.5 | 28.5 | 1.0
2002 | 24.6 | 0.4 | 20.0 | 0.4 | 27.3 | 0.4 | 18.9 | 0.4 | 48.0 | 0.5 | 61.1 | 0.5 | - - - | - - -
2003 | 23.7 | 0.4 | 19.4 | 0.4 | 26.0 | 0.4 | 18.4 | 0.3 | 50.3 | 0.5 | 62.2 | 0.5 | 21.9 | 1.1
2004 | 23.0 | 0.4 | 18.7 | 0.4 | 25.5 | 0.4 | 17.9 | 0.3 | 51.5 | 0.5 | 63.4 | 0.5 | - - - | - - -
2005 | 23.4 | 0.5 | 18.3 | 0.4 | 25.5 | 0.4 | 18.1 | 0.3 | 51.1 | 0.5 | 63.6 | 0.4 | 23.0 | 1.2
2006 | 23.6 | 0.5 | 18.1 | 0.4 | 24.8 | 0.5 | 17.4 | 0.4 | 51.6 | 0.6 | 64.5 | 0.6 | - - - | - - -
2007 | 22.0 | 0.5 | 17.5 | 0.5 | 25.6 | 0.5 | 17.7 | 0.4 | 52.5 | 0.6 | 64.8 | 0.6 | 20.0 | 1.2

SE is standard error.

- - - Data not available.

NOTES: Data for men and women are for the civilian noninstitutionalized population. Estimates for men and women are age-adjusted to the 2000 standard population using five age groups: 18–24 years, 25–34 years, 35–44 years, 45–64 years, and 65 years and over. Age-adjusted estimates in this table may differ from other age-adjusted estimates based on the same data and presented elsewhere if different age groups are used in the adjustment procedure. Cigarette smoking is defined as follows: among men and women 18 years of age and over, those who ever smoked 100 cigarettes in their lifetime and now smoke every day or some days; among high school students in grades 9–12, those who smoked cigarettes on one or more of the 30 days preceding the survey. (See Appendix II, Age adjustment; Cigarette smoking; Tobacco use. Also see Tables 60–62.)

SOURCES: CDC/NCHS, National Health Interview Survey (data for men and women); National Center for Chronic Disease Prevention and Health Promotion, Youth Risk Behavior Survey (data for high school students).

Data table for Figure 7 Overweight and obesity, by age: United States, 1960–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig07.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig07.ppt)

NOTE: See Chartbook Figure for Table 7

| Preschool-age children 2–5 years | | School-age children 6–11 years | | Adolescents 12–19 years | | Adults 20–74 years
| Overweight | | | | | | Overweight including obese | | Overweight but not obese | | Obese
Year | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE
1960–1962 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 44.8 | 1.0 | 31.5 | 0.5 | 13.3 | 0.6
1963–1965 | - - ‐ | - - ‐ | 4.2 | 0.4 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐
1966–1970 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 4.6 | 0.3 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐
1971–1974 | 5.0 | - - ‐ | 4.0 | 0.5 | 6.1 | 0.6 | 47.7 | 0.7 | 33.1 | 0.6 | 14.6 | 0.5
1976–1980 | 5.0 | - - ‐ | 6.5 | 0.6 | 5.0 | 0.5 | 47.4 | 0.8 | 32.3 | 0.6 | 15.1 | 0.5
1988–1994 | 7.2 | 0.7 | 11.3 | 1.0 | 10.5 | 0.9 | 56.0 | 0.9 | 32.7 | 0.6 | 23.3 | 0.7
1999–2000 | 10.3 | 1.7 | 15.1 | 1.4 | 14.8 | 0.9 | 64.1 | 1.9 | 33.1 | 1.1 | 31.0 | 1.5
2001–2002 | 10.6 | 1.8 | 16.3 | 1.6 | 16.7 | 1.1 | 65.7 | 0.9 | 33.6 | 1.1 | 32.1 | 1.2
2003–2004 | 13.9 | 1.6 | 18.8 | 1.3 | 17.4 | 1.7 | 67.1 | 1.3 | 33.2 | 1.1 | 33.9 | 1.3
2005–2006 | 11.0 | 1.2 | 15.1 | 2.1 | 17.8 | 1.8 | 67.3 | 1.3 | 32.1 | 0.9 | 35.2 | 1.5

SE is standard error

- - - Data not available

NOTES: Data are for the civilian noninstitutionalized population Estimates for adults are age-adjusted to the 2000 standard population using five age groups: 20–34 years, 35–44 years, 45–54 years, 55–64 years, and 65–74 years Age-adjusted estimates in this table may differ from other age-adjusted estimates based on the same data and presented elsewhere if different age groups are used in the adjustment procedure For children and adolescents, overweight is defined as a body mass index (BMI) at or above the sex- and age-specific 95th percentile BMI cut points from the 2000 CDC Growth Charts: United States (See: wwwcdcgov/growthcharts/); obese is not defined for children For adults, overweight including obese is defined as a BMI greater than or equal to 25; overweight but not obese as a BMI greater than or equal to 25 but less than 30; and obese as a BMI greater than or equal to 30 Data for 1966–1970 are for adolescents 12–17 years, not 12–19 years of age Pregnant adolescents were excluded beginning in 1971–1974 Pregnant women 20 years of age and over were excluded in all years (See Appendix II, Age adjustment; Body mass index Also see Tables 67, 72, and 73)

SOURCES: CDC/NCHS, National Health Examination Survey and National Health and Nutrition Examination Survey Estimates of overweight for children 2–5 years of age for 1971–1974 and 1976–1980 from: CDC/NCHS Prevalence of overweight among children and adolescents: United States, 2003–2004 Health E-stats Hyattsville, MD: NCHS; 2006

Data table for Figure 8 Trouble sleeping or sleeping pill use in the past month among adults 18 years of age and over, by sex and age: United States, 2005–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig08.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig08.ppt)

NOTE: See Chartbook Figure for Table 8

| Both sexes | | Men | | Women
Age | Percent | SE | Percent | SE | Percent | SE
Adults who often or almost always had trouble sleeping in the past month
18 years and over | 30.3 | 0.7 | 25.9 | 0.8 | 34.4 | 1.0
18–44 years | 27.8 | 1.0 | 23.3 | 1.2 | 32.2 | 1.8
45–64 years | 32.8 | 1.0 | 27.8 | 1.5 | 37.7 | 1.4
65 years and over | 32.7 | 1.3 | 30.4 | 2.2 | 34.3 | 1.7
65–74 years | 33.6 | 2.4 | 28.3 | 2.8 | 37.8 | 3.5
75 years and over | 31.5 | 2.0 | 33.3 | 3.1 | 30.3 | 2.1
Adults who often or almost always took sleeping pills or medications to help them sleep in the past month
18 years and over | 8.8 | 0.7 | 5.3 | 0.6 | 12.1 | 0.8
18–44 years | 5.6 | 0.5 | 2.8 | 0.3 | 8.3 | 0.9
45–64 years | 11.5 | 1.3 | 6.6 | 1.6 | 16.3 | 1.6
65 years and over | 13.5 | 1.2 | 11.3 | 1.5 | 15.2 | 1.4
65–74 years | 12.9 | 1.9 | 11.0 | 2.1 | 14.4 | 2.6
75 years and over | 14.3 | 1.3 | 11.7 | 1.7 | 16.1 | 1.8

SE is standard error

NOTES: For trouble sleeping, respondents reported they often or almost always (5–30 times in the past month) had trouble falling asleep, woke up during the night and had trouble getting back to sleep, or woke up too early in the morning and were unable to get back to sleep For sleeping pills or medications, often or almost always is defined as 5–30 times in the past month

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey

Data table for Figure 9 Influenza and pneumococcal vaccination among middle-age and older adults, by age: United States, 1989–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig09.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig09.ppt)

NOTE: See Chartbook Figure for Table 9

| Influenza vaccination in the past 12 months
| 50–64 years | | 65–74 years | | 75–84 years | | 85 years and over
Year | Percent | SE | Percent | SE | Percent | SE | Percent | SE
1989 | 10.6 | 0.3 | 28.0 | 0.6 | 34.8 | 0.8 | 32.0 | 1.9
1991 | 15.0 | 0.5 | 38.7 | 0.8 | 46.3 | 1.2 | 46.3 | 2.3
1993 | 23.0 | 0.8 | 50.4 | 1.1 | 54.8 | 1.5 | 52.1 | 3.1
1994 | 25.6 | 0.9 | 53.5 | 1.2 | 58.6 | 1.5 | 55.0 | 3.0
1995 | 27.0 | 0.9 | 54.9 | 1.2 | 64.3 | 1.7 | 58.0 | 3.1
1997 | 31.9 | 0.7 | 60.9 | 0.9 | 66.0 | 1.1 | 67.4 | 2.1
1998 | 33.1 | 0.7 | 60.1 | 1.0 | 67.3 | 1.2 | 67.4 | 2.1
1999 | 34.1 | 0.7 | 61.9 | 1.0 | 70.9 | 1.2 | 68.6 | 2.1
2000 | 34.6 | 0.7 | 61.1 | 1.0 | 68.6 | 1.1 | 67.7 | 2.2
2001 | 32.2 | 0.7 | 60.7 | 1.0 | 65.7 | 1.1 | 66.4 | 2.1
2002 | 34.0 | 0.7 | 60.9 | 1.0 | 71.6 | 1.1 | 70.3 | 2.0
2003 | 36.8 | 0.7 | 60.5 | 1.0 | 72.4 | 1.1 | 66.6 | 2.1
2004 | 35.9 | 0.7 | 60.1 | 1.0 | 69.3 | 1.1 | 71.0 | 2.0
2005 | 23.0 | 0.6 | 53.7 | 1.0 | 65.3 | 1.2 | 69.9 | 1.9
2006 | 33.2 | 0.8 | 60.1 | 1.3 | 68.5 | 1.3 | 71.2 | 2.3
2007 | 36.2 | 0.9 | 61.6 | 1.2 | 71.9 | 1.3 | 74.6 | 2.4
| Pneumococcal vaccination ever
| 65 years and over | | 65–74 years | | 75–84 years | | 85 years and over
Year | Percent | SE | Percent | SE | Percent | SE | Percent | SE
1989 | 14.1 | 0.4 | 13.1 | 0.5 | 16.5 | 0.7 | 12.5 | 1.1
1991 | 21.2 | 0.6 | 19.7 | 0.7 | 23.5 | 0.9 | 23.8 | 2.0
1993 | 28.2 | 0.8 | 26.2 | 1.0 | 31.9 | 1.4 | 27.1 | 3.1
1994 | 29.7 | 0.8 | 28.4 | 1.1 | 31.8 | 1.4 | 30.9 | 2.7
1995 | 34.0 | 0.9 | 31.4 | 1.2 | 39.1 | 1.8 | 33.2 | 2.9
1997 | 42.4 | 0.7 | 40.1 | 1.0 | 46.2 | 1.1 | 42.1 | 2.2
1998 | 46.0 | 0.8 | 42.1 | 1.0 | 51.7 | 1.2 | 47.1 | 2.3
1999 | 49.7 | 0.8 | 46.6 | 1.0 | 54.8 | 1.3 | 49.1 | 2.3
2000 | 53.1 | 0.8 | 48.2 | 1.0 | 59.7 | 1.2 | 56.6 | 2.3
2001 | 54.0 | 0.8 | 50.3 | 1.1 | 58.5 | 1.2 | 58.4 | 2.3
2002 | 56.0 | 0.8 | 50.2 | 1.0 | 62.7 | 1.2 | 63.1 | 2.3
2003 | 55.6 | 0.8 | 49.8 | 1.1 | 63.3 | 1.2 | 58.1 | 2.2
2004 | 56.8 | 0.8 | 50.4 | 1.1 | 64.3 | 1.2 | 64.0 | 2.3
2005 | 56.2 | 0.7 | 49.4 | 1.0 | 64.5 | 1.1 | 61.8 | 2.0
2006 | 57.1 | 0.9 | 52.0 | 1.3 | 63.8 | 1.5 | 60.6 | 2.6
2007 | 57.7 | 0.9 | 51.8 | 1.3 | 64.9 | 1.4 | 62.6 | 2.6

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Estimates are based on two questions: “During the past 12 months, have you had a flu shot?” A flu shot is usually given in the fall and protects against influenza for the flu season. Beginning in September 2003, respondents were asked about influenza vaccination by nasal spray (sometimes called by the brand name FluMist™) during the past 12 months, in addition to the question regarding the flu shot. Starting with 2005 data, receipt of nasal spray or flu shot were included in the calculation of influenza vaccination estimates. Respondents were also asked “Have you ever had a pneumonia shot?” This shot is usually given only once or twice in a person’s lifetime and is different from the flu shot. It is also called pneumococcal vaccine. Annual influenza vaccination has been recommended for all adults 50 years of age and over since 2000, and pneumococcal vaccination has been recommended for all adults 65 years of age and over since 1997. Due to the shortfall in the 2000–2001 and 2004–2005 influenza vaccine supplies, CDC recommended vaccine be reserved for priority groups including those 65 years of age and over and those 2–64 years with chronic underlying health conditions. For more information, see: CDC. Prevention and control of influenza: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR 2000;49(RR-03):1–38. Available from: http://www.cdc.gov/mmwr/PDF/rr/rr4903.pdf; CDC. Prevention of pneumococcal disease: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR 1997;46(RR–08):1–24. Available from: http://www.cdc.gov/mmwr/PDF/rr/rr4608.pdf; CDC. Interim influenza vaccination recommendations, 2004–05 influenza season. MMWR 2004; 53(39):923–4. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5339a6.htm; CDC. Notice to readers: Updated recommendations from the Advisory Committee on Immunization Practices in response to delays in supply of influenza vaccine for the 2000–01 season. MMWR 2000;49(39);888–92. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm4927a4.htm.

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 10 Hypertension, diabetes, and serious heart conditions among adults 45 years of age and over, by age and percent of poverty level: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig10.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig10.ppt)

NOTE: See Chartbook Figure for Table 10

| Physician-diagnosed condition
| Hypertension | | Diabetes | | Serious heart conditions
Age and percent of poverty level | Percent | SE | Percent | SE | Percent | SE
45–64 years
Total | 32.1 | 0.6 | 10.6 | 0.4 | 6.7 | 0.4
Below poverty | 46.3 | 2.3 | 18.7 | 1.5 | 12.0 | 1.3
100%–less than 200% | 37.5 | 2.2 | 15.8 | 1.5 | 9.8 | 1.1
200% or more | 29.6 | 0.7 | 8.9 | 0.5 | 5.6 | 0.4
65–74 years
Total | 50.9 | 1.2 | 20.0 | 0.9 | 18.6 | 1.0
Below poverty | 59.5 | 3.8 | 26.0 | 3.1 | 21.4 | 3.1
100%–less than 200% | 56.1 | 2.4 | 24.4 | 2.4 | 18.2 | 1.8
200% or more | 48.2 | 1.4 | 17.8 | 1.2 | 18.4 | 1.2
75 years and over
Total | 57.4 | 1.3 | 17.3 | 1.0 | 23.6 | 1.1
Below poverty | 56.8 | 4.4 | 19.9 | 3.2 | 24.3 | 3.2
100%–less than 200% | 57.9 | 2.4 | 16.2 | 1.7 | 23.4 | 2.2
200% or more | 57.2 | 1.9 | 17.3 | 1.4 | 23.5 | 1.5

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Persons who reported more than one condition were counted in each category. Conditions refer to response categories in the National Health Interview Survey; some conditions include several response categories. Conditions were determined by asking if a doctor or other health professional ever told the respondent that they had a specified condition. Persons reporting borderline diabetes are recoded to not diabetic. Heart disease includes coronary heart disease, angina or angina pectoris, or heart attack or myocardial infarction. Hypertension is told on two or more different visits. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 37% of adults 45 years of age and over in 2007. (See Appendix II, Family income; Poverty.)

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 11 Nonfatal occupational injuries and illnesses in private industry: United States, 1989–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig11.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig11.ppt)

NOTE: See Chartbook Figure for Table 11

Year | Total injury and illness cases | Injury cases
| Number per 100 full-time workers
1989 | 8.6 | 8.2
1990 | 8.8 | 8.3
1991 | 8.4 | 7.9
1992 (OSHA recordkeeping change) | 8.9 | 8.3
1993 | 8.5 | 7.9
1994 | 8.4 | 7.7
1995 (OSHA data initiative) | 8.1 | 7.5
1996 | 7.4 | 6.9
1997 | 7.1 | 6.6
1998 | 6.7 | 6.2
1999 | 6.3 | 5.9
2000 | 6.1 | 5.8
2001 | 5.7 | 5.4
2002 (OSHA recordkeeping change) | 5.3 | 5.0
2003 | 5.0 | 4.7
2004 | 4.8 | 4.5
2005 | 4.6 | 4.4
2006 | 4.4 | 4.2
2007 | 4.2 | 4.0

OSHA is Occupational Safety and Health Administration.

NOTES: Recordkeeping and data collection changes introduced in 1992, 1995, and 2002 may affect the data; therefore, caution should be used when interpreting trends. For more information, see the Technical Notes. (See Appendix I, Survey of Occupational Injuries and Illnesses. Also see Tables 44–46.)

SOURCE: U.S. Department of Labor, Bureau of Labor Statistics, Survey of Occupational Injuries and Illnesses. Available from: http://www.bls.gov/iif/home.htm.

Data table for Figure 12 Depression among adults 18 years of age and over, by sex and age: United States, 2005–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig12.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig12.ppt)

NOTE: See Chartbook Figure for Table 12

Characteristic | Percent | SE
Total | 5.5 | 0.5
Sex
Men | 4.4 | 0.4
Women | 6.6 | 0.7
Age
18–39 years | 4.7 | 0.6
40–59 years | 7.3 | 0.9
60 years and over | 4.0 | 0.7
Sex and age
Men:
18–39 years | 3.5 | 0.6
40–59 years | 5.9 | 0.8
60 years and over | * | *
Women:
18–39 years | 5.9 | 0.9
40–59 years | 8.6 | 1.3
60 years and over | 4.5 | 0.9

SE is standard error.

* Estimates are considered unreliable. Data not shown have a relative standard error greater than 30%.

NOTES: Data are for the civilian noninstitutionalized population. The nine-item Patient Health Questionnaire was used to identify persons with depression. Respondents were asked a series of questions about the frequency of symptoms of depression over the past 2 weeks. Response categories were given a score and summed across questions, yielding a total score ranging from 0 to 27. Respondents with a total score of 10 or higher were classified as having depression. For more information, see the Technical Notes, and see: Pratt LA, Brody DJ. Depression in the United States household population, 2005–2006. NCHS data brief no 7; Hyattsville, MD: NCHS; 2008.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 13 Limitation of activity caused by selected chronic health conditions among children, by age: United States, 2006–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig13.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig13.ppt)

NOTE: See Chartbook Figure for Table 13

| Under 5 years | | 5–11 years | | 12–17 years
Type of chronic health condition | Rate | SE | Rate | SE | Rate | SE
| Number of children with limitation of activity caused by selected chronic health conditions per 1,000 population
Speech problem | 15.8 | 1.5 | 23.1 | 1.5 | 7.7 | 0.9
Asthma or breathing problem | 6.9 | 0.9 | 4.4 | 0.5 | 5.7 | 0.7
Mental retardation or other developmental problem | 6.5 | 1.1 | 10.1 | 1.0 | 11.2 | 1.1
Other mental, emotional, or behavioral problem | 3.8 | 0.7 | 14.1 | 1.2 | 14.9 | 1.3
Attention-deficit/hyperactivity disorder | * | * | 19.0 | 1.4 | 24.7 | 1.8
Learning disability | *2.4 | 0.6 | 20.0 | 1.5 | 31.6 | 1.8

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE greater than 30%.

NOTES: Data are for noninstitutionalized children. Children with limitation of activity caused by chronic health conditions were identified either by their enrollment in special programs (special education or early intervention services) or by a limitation in their ability to perform activities usual for their age group because of a physical, mental, or emotional problem. Conditions refer to response categories in the National Health Interview Survey. Children with more than one chronic health condition causing activity limitation were counted in each condition category. Starting with 2001 data, the condition list for children was expanded to include categories for attention-deficit/hyperactivity disorder (ADHD or ADD) and learning disability. Thus, comparable data for this figure are not available prior to 2001. (See Appendix II, Condition; Limitation of activity.)

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 14 Limitation of activity caused by selected chronic health conditions among working-age adults, by age: United States, 2006–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig14.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig14.ppt)

NOTE: See Chartbook Figure for Table 14

| 18–44 years | | 45–54 years | | 55–64 years
Type of chronic health condition | Rate | SE | Rate | SE | Rate | SE
| Number of persons with limitation of activity caused by selected chronic health conditions per 1,000 population
Mental illness. | 13.8 | 0.7 | 23.4 | 1.2 | 28.1 | 1.7
Fractures or joint injury | 5.0 | 0.4 | 13.0 | 0.9 | 19.0 | 1.2
Lung | 4.2 | 0.3 | 11.5 | 0.9 | 19.3 | 1.3
Diabetes | 2.8 | 0.3 | 14.2 | 1.0 | 31.4 | 1.7
Heart or other circulatory | 5.7 | 0.4 | 26.5 | 1.4 | 60.8 | 2.5
Arthritis or other musculoskeletal | 18.6 | 0.7 | 57.8 | 2.2 | 98.6 | 3.0
Mental retardation | 5.5 | 0.4 | 4.4 | 0.6 | 2.6 | 0.5

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Conditions refer to response categories in the National Health Interview Survey; some conditions include several response categories. Mental illness includes depression, anxiety or emotional problem, and other mental conditions. Heart or other circulatory includes heart problem, stroke problem, hypertension or high blood pressure, and other circulatory system conditions. Arthritis or other musculoskeletal includes arthritis or rheumatism, back or neck problem, and other musculoskeletal system conditions. Mental retardation includes mental retardation and other developmental problems (e.g., cerebral palsy). Persons with more than one chronic health condition causing activity limitation were counted in each condition category. (See Appendix II, Condition; Limitation of activity.)

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 15 Limitation of activity caused by selected chronic health conditions among older adults, by age: United States, 2006–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig15.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig15.ppt)

NOTE: See Chartbook Figure for Table 15

| 65–74 years | | 75–84 years | | 85 years and over
Type of chronic health condition | Rate | SE | Rate | SE | Rate | SE
| Number of persons with limitation of activity caused by selected chronic health conditions per 1,000 population
Senility or dementia | 9.2 | 1.1 | 33.5 | 2.9 | 83.4 | 7.5
Lung | 36.0 | 2.4 | 41.9 | 3.1 | 37.7 | 4.9
Diabetes | 41.1 | 2.4 | 44.1 | 3.0 | 49.6 | 6.3
Vision | 17.0 | 1.7 | 31.2 | 2.7 | 88.5 | 8.4
Hearing | 8.5 | 1.1 | 21.7 | 2.4 | 72.3 | 8.3
Heart or other circulatory | 96.1 | 3.8 | 137.5 | 5.7 | 203.6 | 12.4
Arthritis or other musculoskeletal | 121.5 | 4.3 | 166.6 | 6.2 | 281.3 | 13.4

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Conditions refer to response categories in the National Health Interview Survey; some conditions include several response categories. Vision includes vision conditions or problems seeing, and hearing includes hearing problems. Heart or other circulatory includes heart problem, stroke problem, hypertension or high blood pressure, and other circulatory system conditions. Arthritis or other musculoskeletal includes arthritis or rheumatism, back or neck problem, and other musculoskeletal system conditions. Senility is the term offered to respondents on a flashcard, but this category may include Alzheimer’s disease or other types of dementia reported by the respondent. Persons with more than one chronic health condition causing activity limitation were counted in each condition category. (See Appendix II, Condition; Limitation of activity.)

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 16 Life expectancy at birth and at 65 years of age, by race and sex: United States, 1970–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig16.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig16.ppt)

NOTE: See Chartbook Figure for Table 16

Year | Male | Female | White male | Black male | White female | Black female
| Life expectancy in years
At birth
1970 | 67.1 | 74.7 | 68.0 | 60.0 | 75.6 | 68.3
1980 | 70.0 | 77.4 | 70.7 | 63.8 | 78.1 | 72.5
1990 | 71.8 | 78.8 | 72.7 | 64.5 | 79.4 | 73.6
1997 | 73.6 | 79.4 | 74.3 | 67.2 | 79.9 | 74.7
1998 | 73.8 | 79.5 | 74.5 | 67.6 | 80.0 | 74.8
1999 | 73.9 | 79.4 | 74.6 | 67.8 | 79.9 | 74.7
2000 | 74.1 | 79.3 | 74.7 | 68.2 | 79.9 | 75.1
2001 | 74.2 | 79.4 | 74.8 | 68.4 | 79.9 | 75.2
2002 | 74.3 | 79.5 | 74.9 | 68.6 | 79.9 | 75.4
2003 | 74.5 | 79.6 | 75.0 | 68.8 | 80.0 | 75.6
2004 | 74.9 | 79.9 | 75.4 | 69.3 | 80.4 | 76.0
2005 | 74.9 | 79.9 | 75.4 | 69.3 | 80.4 | 76.1
2006 | 75.1 | 80.2 | 75.7 | 69.7 | 80.6 | 76.5
At 65 years
1970 | 13.1 | 17.0 | 13.1 | 12.5 | 17.1 | 15.7
1980 | 14.1 | 18.3 | 14.2 | 13.0 | 18.4 | 16.8
1990 | 15.1 | 18.9 | 15.2 | 13.2 | 19.1 | 17.2
1997 | 15.9 | 19.2 | 16.0 | 14.2 | 19.3 | 17.6
1998 | 16.0 | 19.2 | 16.1 | 14.3 | 19.3 | 17.4
1999 | 16.1 | 19.1 | 16.1 | 14.3 | 19.2 | 17.3
2000 | 16.0 | 19.0 | 16.1 | 14.1 | 19.1 | 17.5
2001 | 16.2 | 19.0 | 16.3 | 14.2 | 19.1 | 17.6
2002 | 16.2 | 19.1 | 16.3 | 14.4 | 19.2 | 17.7
2003 | 16.4 | 19.2 | 16.5 | 14.5 | 19.3 | 17.9
2004 | 16.7 | 19.5 | 16.8 | 14.8 | 19.5 | 18.2
2005 | 16.8 | 19.5 | 16.9 | 14.9 | 19.5 | 18.2
2006 | 17.0 | 19.7 | 17.1 | 15.1 | 19.8 | 18.6

NOTES: Death rates used to calculate life expectancies for 1997–1999 are based on postcensal 1990-based population estimates; life expectancies for 2000 and beyond are calculated with death rates based on Census 2000. Data for 2000–2006 are based on a newly revised methodology and may differ from previous editions of Health, United States. (See Appendix I, Population Census and Population Estimates.) Deaths to nonresidents were excluded beginning in 1970. (See Appendix II, Life expectancy. Also see Table 24.)

SOURCES: CDC/NCHS. Heron M, Hoyert DL, Murphy SL, Xu J, Kochanek KD, Tejada-Vera B. Deaths: Final data for 2006. National vital statistics reports; vol 57 no 14. Hyattsville, MD: NCHS; 2009. Arias E. United States life tables, 1997–2004. National vital statistics reports; Hyattsville, MD: NCHS; 1999–2006 and unpublished data.

Data table for Figure 17 Infant, neonatal, and postneonatal mortality rates: United States, 1950–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig17.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig17.ppt)

NOTE: See Chartbook Figure for Table 17

Year | Infant | Neonatal | Postneonatal
| Deaths per 1,000 live births
1950 | 29.21 | 20.50 | 8.71
1960 | 26.04 | 18.73 | 7.31
1970 | 20.01 | 15.08 | 4.93
1980 | 12.60 | 8.48 | 4.13
1981 | 11.93 | 8.02 | 3.91
1982 | 11.52 | 7.70 | 3.82
1983 | 11.16 | 7.28 | 3.88
1984 | 10.79 | 7.00 | 3.79
1985 | 10.64 | 6.96 | 3.68
1986 | 10.35 | 6.71 | 3.64
1987 | 10.08 | 6.46 | 3.62
1988 | 9.95 | 6.32 | 3.64
1989 | 9.81 | 6.23 | 3.59
1990 | 9.22 | 5.85 | 3.38
1991 | 8.94 | 5.59 | 3.35
1992 | 8.52 | 5.37 | 3.14
1993 | 8.37 | 5.29 | 3.07
1994 | 8.02 | 5.12 | 2.90
1995 | 7.59 | 4.91 | 2.67
1996 | 7.32 | 4.77 | 2.55
1997 | 7.23 | 4.77 | 2.45
1998 | 7.20 | 4.80 | 2.40
1999 | 7.06 | 4.73 | 2.33
2000 | 6.91 | 4.63 | 2.28
2001 | 6.85 | 4.54 | 2.31
2002 | 6.97 | 4.66 | 2.31
2003 | 6.85 | 4.62 | 2.23
2004 | 6.79 | 4.52 | 2.27
2005 | 6.87 | 4.54 | 2.34
2006 | 6.69 | 4.45 | 2.24

NOTES: Infant is defined as under 1 year of age, neonatal as under 28 days of age, and postneonatal as 28 days through 11 months of life. (Also see Table 21.)

SOURCE: CDC/NCHS, National Vital Statistics System: Heron M, Hoyert DL, Murphy SL, Xu J, Kochanek KD, Tejada-Vera B. Deaths: Final data for 2006. National vital statistics reports; vol 57 no 14. Hyattsville, MD: NCHS; 2009. Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr57/nvsr57_14.pdf.

Data table for Figure 18 Death rates for leading causes of death for all ages: United States, 1950–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig18.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig18.ppt)

NOTE: See Chartbook Figure for Table 18

Year | All causes | Heart disease | Cancer | Stroke | Chronic lower respiratory diseases | Unintentional injuries | Diabetes
| Deaths per 100,000 population
1950 | 1,446.0 | 586.8 | 193.9 | 180.7 | - - - | 78.0 | 23.1
1960 | 1,339.2 | 559.0 | 193.9 | 177.9 | - - - | 62.3 | 22.5
1970 | 1,222.6 | 492.7 | 198.6 | 147.7 | - - - | 60.1 | 24.3
1980 | 1,039.1 | 412.1 | 207.9 | 96.2 | 28.3 | 46.4 | 18.1
1981 | 1,007.1 | 397.0 | 206.4 | 89.5 | 29.0 | 43.4 | 17.6
1982 | 985.0 | 389.0 | 208.3 | 84.2 | 29.1 | 40.1 | 17.2
1983 | 990.0 | 388.9 | 209.1 | 81.2 | 31.6 | 39.1 | 17.6
1984 | 982.5 | 378.8 | 210.8 | 78.7 | 32.4 | 38.8 | 17.2
1985 | 988.1 | 375.0 | 211.3 | 76.4 | 34.5 | 38.5 | 17.4
1986 | 978.6 | 365.1 | 211.5 | 73.1 | 34.8 | 38.6 | 17.2
1987 | 970.0 | 355.9 | 211.7 | 71.6 | 35.0 | 38.2 | 17.4
1988 | 975.7 | 352.5 | 212.5 | 70.6 | 36.5 | 38.9 | 18.0
1989 | 950.5 | 332.0 | 214.2 | 66.9 | 36.6 | 37.7 | 20.5
1990 | 938.7 | 321.8 | 216.0 | 65.3 | 37.2 | 36.3 | 20.7
1991 | 922.3 | 312.5 | 215.2 | 62.9 | 37.9 | 34.7 | 20.7
1992 | 905.6 | 304.0 | 213.5 | 61.5 | 37.7 | 33.2 | 20.7
1993 | 926.1 | 308.1 | 213.5 | 62.7 | 40.7 | 34.2 | 21.9
1994 | 913.5 | 297.5 | 211.7 | 62.6 | 40.3 | 34.2 | 22.6
1995 | 909.8 | 293.4 | 209.9 | 63.1 | 40.1 | 34.4 | 23.2
1996 | 894.1 | 285.7 | 206.7 | 62.5 | 40.6 | 34.5 | 23.8
1997 | 878.1 | 277.7 | 203.4 | 61.1 | 41.1 | 34.2 | 23.7
1998 | 870.6 | 271.3 | 200.7 | 59.3 | 41.8 | 34.5 | 24.0
1998 (comparability-modified) | 870.6 | 267.4 | 202.1 | 62.8 | 43.8 | 35.6 | 24.2
1999 | 875.6 | 266.5 | 200.8 | 61.6 | 45.4 | 35.3 | 25.0
2000 | 869.0 | 257.6 | 199.6 | 60.9 | 44.2 | 34.9 | 25.0
2001 | 854.5 | 247.8 | 196.0 | 57.9 | 43.7 | 35.7 | 25.3
2002 | 845.3 | 240.8 | 193.5 | 56.2 | 43.5 | 36.9 | 25.4
2003 | 832.7 | 232.3 | 190.1 | 53.5 | 43.3 | 37.3 | 25.3
2004 | 800.8 | 217.0 | 185.8 | 50.0 | 41.1 | 37.7 | 24.5
2005 | 798.8 | 211.1 | 183.8 | 46.6 | 43.2 | 39.1 | 24.6
2006 | 776.5 | 200.2 | 180.7 | 43.6 | 40.5 | 39.8 | 23.3

- - - Data not available.

NOTES: Estimates are age-adjusted to the year 2000 standard population using the following age groups: under 1 year, 1–4 years, 10-year age groups from 5–14 through 75–84 years, and 85 years and over. Causes of death shown are the six leading causes of death for all ages in 2006. The 1950 death rates are based on the sixth revision of the International Classification of Diseases (ICD–6), 1960 death rates on ICD–7, 1970 death rates on ICD–8, and 1980–1998 death rates on ICD–9. The 1998 (comparability-modified) death rates use comparability ratios to adjust the rate to be comparable to records classified according to ICD–10. Starting with 1999 data, death rates are based on ICD–10. Comparability ratios across revisions for selected causes are available from: http://www.cdc.gov/nchs/data/statab/comp2.pdf. Death rates for chronic lower respiratory diseases are available from 1980, when a category that included bronchitis, emphysema, asthma, and other chronic lung diseases was introduced in ICD–9. Cancer refers to malignant neoplasms; stroke to cerebrovascular diseases; and unintentional injuries is preferred to accidents in the public health community. Rates for 1981–1989 were computed using intercensal population estimates based on the 1990 census. Rates for 1991–1999 were computed using intercensal population estimates based on the 2000 census. Rates for 2000 were computed using 2000 census counts. Rates for 2001 and later years were computed using 2000-based postcensal estimates. (See Appendix I, Population Census and Population Estimates; Appendix II, Age adjustment; Cause of death; Comparability ratio; Table V. Also see related Tables 26, 28, 29, and 31–34.)

SOURCE: CDC/NCHS, National Vital Statistics System.

Data table for Figure 19 Health insurance coverage at the time of interview among persons under 65 years of age: United States, 1984–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig19.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig19.ppt)

NOTE: See Chartbook Figure for Table 19

| Health insurance coverage at the time of interview
| Private | | Medicaid | | Uninsured
Year | Percent | SE | Percent | SE | Percent | SE
1984 | 76.8 | 0.6 | 6.8 | 0.3 | 14.5 | 0.4
1989 | 75.9 | 0.4 | 7.2 | 0.2 | 15.6 | 0.3
1994 | 69.9 | 0.4 | 11.2 | 0.3 | 17.5 | 0.3
1995 | 71.3 | 0.4 | 11.5 | 0.2 | 16.1 | 0.2
1996 | 71.2 | 0.5 | 11.1 | 0.3 | 16.6 | 0.3
1997 | 70.7 | 0.4 | 9.7 | 0.2 | 17.5 | 0.2
1998 | 72.1 | 0.4 | 8.9 | 0.2 | 16.6 | 0.2
1999 | 72.8 | 0.3 | 9.1 | 0.2 | 16.1 | 0.2
2000 | 71.5 | 0.4 | 9.5 | 0.2 | 17.0 | 0.3
2001 | 71.2 | 0.4 | 10.4 | 0.2 | 16.4 | 0.3
2002 | 69.4 | 0.4 | 11.8 | 0.2 | 16.8 | 0.2
2003 | 68.9 | 0.4 | 12.3 | 0.2 | 16.5 | 0.3
2004 | 68.8 | 0.4 | 12.5 | 0.2 | 16.4 | 0.2
2005 | 68.2 | 0.4 | 12.9 | 0.2 | 16.4 | 0.2
2006 | 66.3 | 0.5 | 14.0 | 0.3 | 17.0 | 0.3
2007 | 66.8 | 0.4 | 13.9 | 0.3 | 16.6 | 0.3

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Medicaid includes other public assistance through 1996; includes state-sponsored health plans starting in 1997; and includes Children’s Health Insurance Program (CHIP) starting in 1999. Uninsured persons are not covered by private insurance, Medicaid, CHIP, public assistance (through 1996), state-sponsored or other government-sponsored health plans (starting in 1997), Medicare, or military plans. Persons with Indian Health Service only are considered to have no coverage. Percents do not add to 100 because the percentage of persons with Medicare, military plans, and other government-sponsored plans is not shown and because persons with both private insurance and Medicaid appear in both categories. Starting with data from the third quarter of 2004, persons under 65 years of age with no reported coverage were asked explicitly about Medicaid coverage. Estimates for Medicaid coverage shown in this table include the additional information. Estimates for 2000–2002 were calculated using 2000-based sample weights and may differ from estimates in other reports that used 1990-based sample weights for 2000–2002 estimates. (See Appendix II, Health insurance coverage. Also see Tables 137, 139, and 140.)

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 20 Uninsured for at least part of the 12 months prior to interview among persons under 65 years of age, by length of time uninsured and selected characteristics: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig20.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig20.ppt)

NOTE: See Chartbook Figure for Table 20

| Length of time uninsured prior to interview
| Total uninsured prior to interview | | More than 12 months | | Any period up to 12 months
Characteristic | Percent | SE | Percent | SE | Percent | SE
Age
Under 65 years | 20.7 | 0.3 | 11.7 | 0.2 | 7.8 | 0.2
Under 18 years | 12.7 | 0.4 | 5.0 | 0.3 | 6.7 | 0.3
18–24 years | 34.6 | 0.9 | 18.3 | 0.7 | 14.6 | 0.6
25–34 years | 32.5 | 0.7 | 19.6 | 0.5 | 11.6 | 0.4
35–44 years | 23.2 | 0.6 | 14.0 | 0.4 | 7.8 | 0.3
45–54 years | 17.5 | 0.5 | 11.4 | 0.4 | 5.0 | 0.3
55–64 years | 13.3 | 0.5 | 9.0 | 0.4 | 3.5 | 0.3
Percent of poverty level
Below 100% | 35.2 | 1.0 | 21.1 | 0.8 | 12.7 | 0.6
100%–less than 150% | 37.1 | 1.2 | 23.7 | 0.9 | 11.9 | 0.7
150%–less than 200% | 33.9 | 1.2 | 21.0 | 1.1 | 11.4 | 0.8
200% or more | 13.7 | 0.3 | 6.9 | 0.2 | 5.8 | 0.2
Race and Hispanic origin
Black or African American only, not Hispanic or Latino | 21.0 | 0.6 | 10.8 | 0.4 | 9.0 | 0.5
Asian only | 17.7 | 1.1 | 11.6 | 0.9 | 5.1 | 0.5
White only, not Hispanic or Latino | 16.7 | 0.4 | 8.4 | 0.3 | 7.3 | 0.2
Hispanic or Latino (total) | 36.2 | 0.7 | 25.7 | 0.6 | 9.5 | 0.4
Mexican | 39.1 | 0.9 | 28.5 | 0.8 | 9.6 | 0.5
Cuban | 22.0 | 2.8 | 17.2 | 2.5 | *4.4 | 1.2
Puerto Rican | 17.7 | 1.5 | 7.9 | 0.9 | 9.0 | 1.2

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: Data are for the civilian noninstitutionalized population. Total uninsured prior to interview includes people uninsured more than 12 months, people uninsured any period up to 12 months, and people uninsured for an unknown length of time (1.3% for persons under 65 years of age). Persons of Hispanic origin may be of any race. Total for Hispanic includes groups not shown separately. Asian only race includes persons of Hispanic and non-Hispanic origin. Uninsured persons are not covered by private insurance, Medicaid, Children’s Health Insurance Program (CHIP), state-sponsored or other government-sponsored health plans, Medicare, or military plans. Persons with Indian Health Service only are considered uninsured. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 31% of persons under 65 years of age in 2007. (See Appendix II, Family income; Health insurance coverage; Hispanic origin; Poverty; Race.)

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 21 Personal health care expenditures, by source of funds and type of expenditures: United States, 2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig21.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig22.ppt)

NOTE: See Chartbook Figure for Table 21

Source of funds | Amount in billions | Percent distribution
All personal health care expenditures | $1,878 | 100.0
All sources of funds:
Private | 1,028 | 54.7
Private health insurance. | 680 | 36.2
Out-of-pocket payments | 269 | 14.3
Other private funds | 79 | 4.2
Public | 851 | 45.3
Medicare | 410 | 21.8
Medicaid (federal) | 177 | 9.4
Medicaid (state) | 135 | 7.2
Other federal | 76 | 4.1
Other state and local | 53 | 2.8
Type of expenditure | Amount in billions | Percent distribution
All personal health care expenditures | $1,878 | 100.0
Hospital care | 697 | 37.1
Physician and clinical services | 479 | 25.5
Prescription drugs | 227 | 12.1
Nursing home care | 131 | 7.0
Dental services | 95 | 5.1
Home health care | 59 | 3.1
Other types of expenditures | 190 | 10.1

NOTES: Percents are calculated using unrounded data. Estimates may not add to total because of rounding. Expenditures for Children’s Health Insurance Program (CHIP) and CHIP expansion are included with Medicaid. Other private funds include industrial in-plant and other private revenues, including charity. Other federal funds include workers’ compensation, Department of Defense, maternal and child health, Veteran’s Administration, vocational rehabilitation, general hospital/medical, Substance Abuse and Mental Health Services Administration, Indian Health Services, and Office of Economic Opportunity. Other state and local funds include temporary disability, workers’ compensation, general assistance, maternal and child health, vocational rehabilitation, state and local hospitalization, and school health. Other types of expenditures include other professional services, other nondurable medical products, durable medical equipment, and other personal health care. (See Appendix I, National Health Expenditure Accounts; Appendix II, Health expenditures, national. Also see Figure 22 and Tables 127 and 128.)

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Expenditure Accounts.

Data table for Figure 22 Personal health care expenditures, by source of funds: United States, 1990–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig22.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig22.ppt)

NOTE: See Chartbook Figure for Table 22

Source of funds | 1990 | 1991 | 1992 | 1993 | 1994 | 1995 | 1996 | 1997 | 1998 | 1999
| Amount in billions
Total personal health care expenditures | $608 | $669 | $726 | $774 | $814 | $863 | $910 | $959 | $1,010 | $1,068
Private funds | 371 | 398 | 423 | 441 | 452 | 477 | 501 | 533 | 575 | 612
Out-of-pocket payments | 136 | 140 | 143 | 145 | 143 | 146 | 152 | 162 | 175 | 184
Private health insurance | 205 | 225 | 243 | 257 | 270 | 286 | 302 | 320 | 344 | 371
Public funds | 236 | 271 | 303 | 333 | 362 | 387 | 409 | 426 | 435 | 456
Federal funds | 173 | 200 | 228 | 252 | 274 | 296 | 316 | 329 | 332 | 346
Medicare | 107 | 117 | 132 | 146 | 163 | 180 | 194 | 204 | 202 | 206
Medicaid including CHIP and CHIP expansion | 40 | 54 | 65 | 73 | 78 | 82 | 88 | 91 | 93 | 101
State and local funds | 63 | 70 | 75 | 81 | 88 | 91 | 93 | 97 | 103 | 109
Medicaid including CHIP and CHIP expansion | 29 | 35 | 38 | 43 | 49 | 54 | 57 | 60 | 65 | 70
| Deflator (2000 = 100.0)
Personal health care implicit price deflator | 70.4 | 74.4 | 78.3 | 81.9 | 84.9 | 87.8 | 90.4 | 92.3 | 94.3 | 96.8
| Adjusted amount in billions
Adjusted dollars (2000 base) | $863 | $899 | $927 | $945 | $959 | $983 | $1,007 | $1,039 | $1,071 | $1,103
| | | | | | | | | Average annual percent change
Source of funds | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 1990–1999 | 2000–2007 | 1990–2007
| Amount in billions
Total personal health care expenditures | $1,139 | $1,238 | $1,340 | $1,448 | $1,550 | $1,655 | $1,765 | $1,878 | 6.5 | 7.4 | 6.9
Private funds | 652 | 697 | 752 | 810 | 860 | 915 | 967 | 1,028 | 5.7 | 6.7 | 6.2
Out-of-pocket payments | 193 | 200 | 211 | 225 | 235 | 247 | 255 | 269 | 3.4 | 4.9 | 4.1
Private health insurance | 403 | 441 | 482 | 521 | 561 | 599 | 638 | 680 | 6.8 | 7.8 | 7.3
Public funds | 487 | 541 | 589 | 638 | 690 | 740 | 799 | 851 | 7.6 | 8.3 | 7.8
Federal funds | 370 | 412 | 448 | 486 | 528 | 563 | 621 | 663 | 8.0 | 8.7 | 8.2
Medicare | 216 | 239 | 256 | 274 | 301 | 327 | 383 | 410 | 7.6 | 9.6 | 8.2
Medicaid including CHIP and CHIP expansion | 110 | 123 | 137 | 149 | 160 | 165 | 161 | 172 | 10.8 | 6.6 | 9.0
State and local funds | 117 | 130 | 140 | 151 | 162 | 177 | 178 | 188 | 6.2 | 7.0 | 6.6
Medicaid including CHIP and CHIP expansion | 77 | 86 | 94 | 102 | 110 | 124 | 124 | 132 | 10.3 | 8.0 | 9.3
| Deflator (2000 = 100.0)
Personal health care implicit price deflator | 100.0 | 103.8 | 107.8 | 111.7 | 116.3 | 120.5 | 124.6 | 128.8 | . . . | . . . | . . .
| Adjusted amount in billions
Adjusted dollars (2000 base) | $1,139 | $1,193 | $1,243 | $1,296 | $1,333 | $1,374 | $1,417 | $1,458 | 2.8 | 3.6 | 3.1

. . . Category not applicable.

CHIP is Children’s Health Insurance Program.

NOTES: CHIP expenditures started in 1998. The personal health care implicit price deflator was constructed from the Producer Price Index for hospital care, Nursing Home Input Price Index for nursing home care, and Consumer Price Indices specific to each of the remaining personal health care components. Expenditures by funder are not adjusted for inflation because there is no price deflator that is appropriate for this adjustment. Personal health care expenditures include all expenditures for specified health services and supplies other than expenses for government administration, net cost of private health insurance, and government public health activities.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Expenditure Accounts. National health expenditures, 2007. Available from: http://www.cms.hhs.gov/NationalHealthExpendData/; and unpublished data.

Data table for Figure 24 Federally regulated (CLIA) laboratories: United States, 1993–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig24.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig24.ppt)

NOTE: See Chartbook Figure for Table 24

| Total laboratories (Nonexempt and exempt states) | | | Laboratories in nonexempt states
Year | All laboratories | Laboratories located in physician offices (POLS) | Percent POLS | Total CLIA laboratories | CLIA-waived laboratories | Percent CLIA-waived laboratories
| Number of laboratories | | | Number of laboratories
1993 | 154,740 | 90,800 | 58.7 | 152,250 | 67,294 | 44.2
1994 | 150,143 | 89,344 | 59.5 | 144,079 | 66,235 | 46.0
1995 | 152,434 | 82,907 | 54.4 | 145,124 | 65,031 | 44.8
1996 | 157,002 | 87,832 | 55.9 | 149,055 | 68,127 | 45.7
1997 | 157,607 | 88,028 | 55.9 | 150,229 | 74,455 | 49.6
1998 | 164,570 | 91,600 | 55.7 | 158,412 | 78,825 | 49.8
1999 | 169,558 | 93,867 | 55.4 | 162,044 | 84,217 | 52.0
2000 | 169,531 | 95,069 | 56.1 | 163,764 | 85,944 | 52.5
2001 | 170,996 | 95,879 | 56.1 | 165,229 | 88,730 | 53.7
2002 | 174,504 | 97,363 | 55.8 | 169,005 | 93,129 | 55.1
2003 | 183,874 | 101,090 | 55.0 | 177,615 | 102,123 | 57.5
2004 | 186,734 | 104,230 | 55.8 | 180,447 | 105,138 | 58.3
2005 | 194,734 | 105,914 | 54.4 | 188,741 | 113,455 | 60.1
2006 | 198,232 | 106,180 | 53.6 | 192,215 | 117,418 | 61.1
2007 | 203,939 | 107,937 | 52.9 | 197,843 | 122,992 | 62.2
2008 | 209,499 | 108,734 | 51.9 | 203,101 | 129,219 | 63.6

CLIA is Clinical Laboratory Improvement Amendments of 1988.

NOTES: New York state and Washington state are exempt from CLIA because they have their own regulatory requirements. Waived laboratories perform only tests that have been classified as waived, which are generally simple with low risk of erroneous results.

SOURCE: Centers for Medicare & Medicaid Services, CLIA Database. Available from http://www.cms.hhs.gov/CLIA/17_CLIA_Statistical_Tables_Graphs.asp#TopOfPage.

Data table for Figure 25 Ambulatory care visits with MRI/CT/PET scans ordered or provided during the visit, by age and location of care: United States, 1996–2007

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig25.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig25.ppt)

NOTE: See Chartbook Figure for Table 25

| Physician office and hospital outpatient department visits | | | | | | Emergency department visits
| All ages | | Under 65 years | | 65 years and over | | All ages | | Under 65 years | | 65 years and over
Year | Visits per 100 persons | SE | Visits per 100 persons | SE | Visits per 100 persons | SE | Visits per 100 persons | SE | Visits per 100 persons | SE | Visits per 100 persons | SE
1996 | 3.9 | 0.4 | 3.2 | 0.3 | 9.0 | 1.3 | 1.2 | 0.1 | 0.9 | 0.1 | 3.2 | 0.3
1997 | 3.7 | 0.3 | 3.1 | 0.3 | 8.4 | 1.1 | 1.3 | 0.1 | 1.0 | 0.1 | 3.3 | 0.3
1998 | 4.3 | 0.4 | 3.5 | 0.3 | 10.3 | 1.4 | 1.6 | 0.1 | 1.2 | 0.1 | 4.1 | 0.5
1999 | 5.4 | 0.6 | 4.6 | 0.5 | 11.4 | 1.9 | 1.9 | 0.1 | 1.5 | 0.1 | 4.3 | 0.4
2000 | 5.6 | 0.5 | 4.6 | 0.4 | 12.7 | 2.0 | 2.1 | 0.1 | 1.7 | 0.1 | 5.5 | 0.4
2001 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 2.4 | 0.1 | 2.0 | 0.1 | 5.8 | 0.4
2002 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 2.8 | 0.2 | 2.2 | 0.1 | 6.9 | 0.5
2003 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 3.1 | 0.1 | 2.5 | 0.1 | 7.5 | 0.6
2004 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 3.6 | 0.2 | 3.0 | 0.2 | 7.7 | 0.6
2005 | 9.2 | 0.8 | 7.3 | 0.7 | 23.0 | 3.2 | 4.4 | 0.2 | 3.7 | 0.2 | 9.5 | 0.6
2006 | 10.3 | 0.7 | 8.2 | 0.6 | 25.7 | 2.4 | 4.8 | 0.3 | 4.1 | 0.2 | 9.9 | 0.6
2007 | 12.6 | 1.1 | 10.0 | 0.9 | 31.1 | 3.2 | 5.6 | 0.4 | 4.7 | 0.3 | 12.5 | 0.9
| Physician office and hospital outpatient department visits | | | | | | Emergency department visits
| All ages | | Under 65 years | | 65 years and over | | All ages | | Under 65 years | | 65 years and over
Year | Percent of visits | SE | Percent of visits | SE | Percent of visits | SE | Percent of visits | SE | Percent of visits | SE | Percent of visits | SE
1996 | 1.3 | 0.1 | 1.2 | 0.1 | 1.5 | 0.2 | 3.4 | 0.2 | 2.7 | 0.2 | 7.7 | 0.6
1997 | 1.1 | 0.1 | 1.1 | 0.1 | 1.3 | 0.2 | 3.7 | 0.2 | 3.1 | 0.2 | 7.2 | 0.5
1998 | 1.3 | 0.1 | 1.2 | 0.1 | 1.6 | 0.2 | 4.2 | 0.3 | 3.4 | 0.2 | 8.6 | 0.8
1999 | 1.8 | 0.2 | 1.7 | 0.2 | 1.8 | 0.3 | 4.9 | 0.2 | 4.2 | 0.2 | 9.0 | 0.6
2000 | 1.7 | 0.1 | 1.6 | 0.1 | 2.0 | 0.3 | 5.4 | 0.2 | 4.4 | 0.2 | 11.3 | 0.7
2001 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 6.3 | 0.3 | 5.3 | 0.3 | 12.2 | 0.7
2002 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 7.1 | 0.3 | 5.9 | 0.3 | 14.2 | 0.7
2003 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 7.9 | 0.3 | 6.6 | 0.3 | 14.6 | 0.8
2004 | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | - - ‐ | 9.3 | 0.4 | 8.1 | 0.4 | 16.9 | 0.8
2005 | 2.6 | 0.2 | 2.4 | 0.2 | 3.1 | 0.4 | 11.0 | 0.4 | 9.5 | 0.4 | 20.0 | 0.9
2006 | 3.0 | 0.2 | 2.8 | 0.2 | 3.7 | 0.4 | 11.9 | 0.5 | 10.5 | 0.4 | 20.3 | 1.0
2007 | 3.4 | 0.2 | 3.2 | 0.2 | 4.1 | 0.4 | 14.2 | 0.5 | 12.2 | 0.5 | 25.8 | 0.8

SE is standard error.

- - - Data not available.

NOTES: The data available for imaging scans differed by the survey location and data year. For emergency department visits: data for all years were collected using a checkbox for MRI or CT scans only, and there was no checkbox for PET scans. For physician office and hospital outpatient department visits: for 1996–2000, data were collected using a checkbox for MRI or CT scans and there was no checkbox for PET scans; for 2001–2004, data for MRI, CT, or PET scans were not collected using a checkbox and were not shown due to lack of comparability with other years; for 2005–2007, data were collected using a checkbox for MRI, CT, or PET scans. In addition to the checkbox for scans, there was a field for including information on other procedures ordered or performed during the visit. In 2005–2007, NCHS coded the information in the other procedure fields if it was for an MRI, CT, or PET scan, and that information was transferred to the checkbox for MRI, CT, or PET scans if it was not already present. To be comparable to the procedure employed in 2005–2007, this analysis included advanced imaging scan information from the write-in fields for 1996–2000. See Technical Notes for a list of procedure codes that were included in the write-in fields for MRI, CT, or PET scans. Rates for 1996–1999 were computed using 1990-based postcensal estimates of the civilian noninstitutionalized population as of July 1 adjusted for net underenumeration using the 1990 National Population Adjustment Matrix from the U.S. Census Bureau. Starting with 2000 data, rates were computed using 2000-based postcensal estimates of the civilian noninstitutionalized population as of July 1.

SOURCES: CDC/NCHS, National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey.

Data table for Figure 26 Use of mammography within the past 2 years among women 40 years of age and over, by race and Hispanic origin: United States, 1987–2008

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig26.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig26.ppt)

NOTE: See Chartbook Figure for Table 26

Characteristic | 1987 | 1990 | 1991 | 1993 | 1994 | 1998 | 1999 | 2000 | 2003 | 2005 | 2008
| Percent of women having a mammogram within the past 2 years
Total women 40 years of age and over, crude | 28.7 | 51.4 | 54.6 | 59.7 | 60.9 | 66.9 | 70.3 | 70.4 | 69.7 | 66.8 | 67.6
Race and Hispanic origin
40 years and over, crude:
Hispanic or Latina | 18.3 | 45.2 | 49.2 | 50.9 | 51.9 | 60.2 | 65.7 | 61.2 | 65.0 | 58.8 | 61.2
Asian only | * | 46.0 | 45.9 | 55.1 | 55.8 | 60.2 | 58.3 | 53.5 | 57.6 | 54.6 | 66.1
Not Hispanic or Latina:
White only | 30.3 | 52.7 | 56.0 | 60.6 | 61.3 | 68.0 | 71.1 | 72.2 | 70.5 | 68.3 | 68.7
Black or African American only | 23.8 | 46.0 | 47.7 | 59.2 | 64.4 | 66.0 | 71.0 | 67.9 | 70.5 | 65.2 | 68.3
| Standard error
Total women 40 years of age and over, crude | 0.7 | 0.6 | 0.5 | 0.7 | 0.7 | 0.5 | 0.5 | 0.6 | 0.5 | 0.6 | 0.7
Race and Hispanic origin
40 years and over, crude:
Hispanic or Latina | 2.3 | 2.4 | 2.4 | 3.2 | 3.4 | 1.7 | 1.8 | 1.7 | 1.6 | 1.7 | 2.1
Asian only | * | 4.5 | 4.1 | 5.6 | 5.5 | 4.0 | 4.3 | 4.3 | 3.6 | 3.5 | 3.0
Not Hispanic or Latina:
White only | 0.7 | 0.7 | 0.6 | 0.8 | 0.8 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.8
Black or African American only | 2.0 | 1.5 | 1.5 | 2.1 | 1.9 | 1.6 | 1.5 | 1.5 | 1.5 | 1.6 | 1.8

* Estimates are considered unreliable. Data not shown have a relative standard error greater than 30%.

NOTES: Data are for the civilian noninstitutionalized population. Persons of Hispanic origin may be of any race. Asian only race includes persons of Hispanic and non-Hispanic origin. Mammography questions differ slightly over time. (See Appendix II, Hispanic origin; Mammography; Race. Also see Table 86.)

SOURCE: CDC/NCHS, National Health Interview Survey.

Data table for Figure 27 Hospital discharges with at least one knee or hip replacement procedure in nonfederal short-stay hospitals among adults 45 years of age and over, by type of procedure, sex, and age: United States, 1996–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig27.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig27.ppt)

NOTE: See Chartbook Figure for Table 27

Type of procedure, sex, and age | 1996 | 1997 | 1998 | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006
Total hip replacement | Discharges per 10,000 population
Both sexes:
45 years and over | 14.7 | 15.2 | 16.5 | 16.5 | 14.2 | 15.4 | 17.7 | 19.2 | 20.4 | 19.9 | 19.4
45–64 years | 6.4 | 6.7 | 8.0 | 9.0 | 8.1 | 8.3 | 10.0 | 10.8 | 11.7 | 10.9 | 12.2
65 years and over | 28.0 | 29.0 | 30.9 | 29.5 | 25.2 | 28.2 | 32.1 | 35.3 | 37.3 | 37.7 | 33.8
Men:
45 years and over | 12.7 | 12.8 | 14.7 | 14.8 | 13.6 | 13.1 | 15.8 | 18.4 | 18.0 | 19.3 | 18.1
45–64 years | 7.4 | 6.9 | 8.3 | 9.7 | 9.1 | 9.5 | 10.5 | 12.7 | 11.4 | 12.3 | 13.1
65 years and over | 22.7 | 24.3 | 27.3 | 25.0 | 23.0 | 20.7 | 27.6 | 31.2 | 32.9 | 35.4 | 29.9
Women:
45 years and over | 16.4 | 17.1 | 18.1 | 18.0 | 14.8 | 17.3 | 19.3 | 19.9 | 22.4 | 20.5 | 20.5
45–64 years | 5.5 | 6.5 | 7.7 | 8.3 | 7.2 | 7.2 | 9.6 | 9.1 | 11.9 | 9.6 | 11.5
65 years and over | 31.7 | 32.4 | 33.4 | 32.7 | 26.6 | 33.5 | 35.3 | 38.2 | 40.5 | 39.4 | 36.6
Partial hip replacement
Both sexes:
45 years and over | 11.7 | 11.5 | 12.2 | 11.2 | 10.5 | 11.7 | 10.5 | 10.2 | 17.9 | 17.5 | 18.8
65 years and over | 27.7 | 28.7 | 30.4 | 27.6 | 27.0 | 31.6 | 27.2 | 28.1 | 35.3 | 34.2 | 37.4
Men:
45 years and over | 6.0 | 6.1 | 6.4 | 6.0 | 4.7 | 5.8 | 6.0 | 6.2 | 13.2 | 13.3 | 13.0
65 years and over | 15.6 | 16.3 | 16.8 | 15.4 | 13.0 | 17.3 | 16.2 | 18.6 | 26.1 | 23.8 | 21.6
Women:
45 years and over | 16.4 | 16.1 | 17.1 | 15.6 | 15.5 | 16.6 | 14.4 | 13.6 | 22.0 | 21.2 | 23.9
65 years and over | 36.1 | 37.4 | 40.0 | 36.4 | 36.9 | 41.6 | 35.1 | 34.9 | 42.0 | 41.7 | 48.8
Total knee replacement
Both sexes:
45 years and over | 26.5 | 27.3 | 27.6 | 27.1 | 29.0 | 30.5 | 34.8 | 37.9 | 41.7 | 46.0 | 45.2
45–64 years | 10.4 | 13.2 | 13.5 | 12.9 | 12.7 | 15.1 | 18.6 | 21.8 | 23.5 | 25.4 | 25.7
65 years and over | 52.1 | 50.3 | 51.3 | 51.6 | 58.0 | 58.6 | 65.0 | 68.6 | 77.2 | 86.7 | 84.1
Men:
45 years and over | 20.6 | 20.2 | 21.8 | 23.0 | 24.3 | 25.0 | 28.4 | 30.0 | 31.0 | 33.9 | 34.9
45–64 years | 8.4 | 9.9 | 11.2 | 10.4 | 8.7 | 11.1 | 14.3 | 17.9 | 14.9 | 17.7 | 19.2
65 years and over | 43.6 | 40.0 | 42.5 | 48.2 | 57.0 | 54.9 | 59.2 | 57.0 | 67.6 | 71.2 | 71.5
Women:
45 years and over | 31.4 | 33.3 | 32.6 | 30.7 | 33.0 | 35.2 | 40.3 | 44.7 | 51.0 | 56.4 | 54.0
45–64 years | 12.4 | 16.3 | 15.7 | 15.3 | 16.4 | 18.9 | 22.8 | 25.5 | 31.6 | 32.7 | 31.9
65 years and over | 58.0 | 57.5 | 57.5 | 54.0 | 58.8 | 61.2 | 69.1 | 76.8 | 84.1 | 97.8 | 93.3
Total hip replacement | Standard error
Both sexes:
45 years and over | 1.2 | 1.1 | 1.2 | 1.3 | 1.1 | 1.3 | 1.3 | 1.8 | 1.8 | 1.8 | 1.8
45–64 years | 0.7 | 0.8 | 0.7 | 0.9 | 1.0 | 0.9 | 1.0 | 1.2 | 1.3 | 1.3 | 1.4
65 years and over | 2.5 | 2.3 | 2.7 | 2.4 | 2.3 | 2.7 | 2.8 | 3.5 | 3.5 | 3.5 | 3.3
Men:
45 years and over | 1.1 | 1.2 | 1.4 | 1.5 | 1.2 | 1.5 | 1.5 | 2.0 | 2.1 | 2.2 | 1.9
45–64 years | 0.9 | 1.2 | 1.1 | 1.4 | 1.4 | 1.5 | 1.4 | 1.7 | 1.5 | 1.7 | 1.7
65 years and over | 2.5 | 2.6 | 3.1 | 2.7 | 2.8 | 2.6 | 3.1 | 4.3 | 4.2 | 4.5 | 3.6
Women:
45 years and over | 1.6 | 1.5 | 1.4 | 1.6 | 1.3 | 1.5 | 1.7 | 1.9 | 1.9 | 1.8 | 2.0
45–64 years | 0.8 | 0.9 | 0.8 | 1.2 | 1.1 | 0.9 | 1.1 | 1.3 | 1.3 | 1.1 | 1.6
65 years and over | 3.4 | 2.9 | 3.1 | 3.1 | 2.6 | 3.2 | 3.5 | 3.9 | 4.0 | 3.8 | 3.7
Partial hip replacement | Standard error
Both sexes:
45 years and over | 0.9 | 0.9 | 1.0 | 0.9 | 0.9 | 1.1 | 0.9 | 0.9 | 1.9 | 1.6 | 1.9
65 years and over | 2.2 | 2.4 | 2.7 | 2.4 | 2.4 | 3.0 | 2.4 | 2.7 | 3.2 | 3.1 | 3.3
Men:
45 years and over | 0.8 | 0.9 | 0.9 | 0.8 | 0.6 | 0.8 | 0.8 | 0.9 | 1.4 | 1.5 | 1.5
65 years and over | 2.1 | 2.7 | 2.5 | 2.1 | 1.7 | 2.4 | 2.6 | 2.8 | 3.0 | 2.6 | 2.3
Women:
45 years and over | 1.4 | 1.3 | 1.6 | 1.4 | 1.5 | 1.6 | 1.3 | 1.3 | 2.4 | 2.0 | 2.4
65 years and over | 3.0 | 3.0 | 3.8 | 3.3 | 3.5 | 4.2 | 3.2 | 3.6 | 4.0 | 4.2 | 4.6
Total knee replacement
Both sexes:
45 years and over | 2.0 | 2.3 | 1.7 | 2.0 | 2.6 | 2.2 | 2.4 | 3.0 | 3.4 | 4.0 | 3.2
45–64 years | 1.0 | 1.1 | 1.2 | 1.1 | 1.3 | 1.2 | 1.5 | 2.2 | 2.1 | 2.2 | 2.1
65 years and over | 4.2 | 5.0 | 3.3 | 4.2 | 5.9 | 5.2 | 5.0 | 5.7 | 6.6 | 7.9 | 6.1
Men:
45 years and over | 2.0 | 1.6 | 1.8 | 1.9 | 2.5 | 2.4 | 2.7 | 3.1 | 3.6 | 2.9 | 2.9
45–64 years | 1.1 | 1.2 | 1.4 | 1.1 | 1.2 | 1.2 | 1.9 | 3.0 | 1.7 | 1.8 | 2.0
65 years and over | 4.6 | 3.7 | 4.4 | 4.8 | 6.5 | 6.4 | 7.1 | 5.8 | 9.5 | 6.8 | 6.6
Women:
45 years and over | 2.3 | 3.5 | 2.5 | 2.4 | 3.0 | 2.5 | 2.6 | 3.7 | 3.8 | 5.3 | 3.7
45–64 years | 1.4 | 1.8 | 1.7 | 1.6 | 1.9 | 1.8 | 1.8 | 2.6 | 3.1 | 3.2 | 2.7
65 years and over | 4.7 | 7.3 | 4.9 | 4.6 | 5.9 | 5.2 | 5.1 | 6.6 | 6.1 | 9.5 | 6.6

NOTES: Rates are based on the civilian population. Total hip replacement is International Classification of Diseases, ninth revision, Clinical Modification (ICD–9–CM) procedure code 81.51. Partial hip replacement is procedure code 81.52. Total knee replacement is procedure code 81.54.

SOURCE: CDC/NCHS, National Hospital Discharge Survey.

Data table for Figure 28 Hospital discharges with a PTCA procedure among persons 45 years of age and over, by type of procedure, sex, and age: United States, 1996–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig28.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig28.ppt)

NOTE: See Chartbook Figure for Table 28

Type of procedure, sex, and age | 1996 | 1997 | 1998 | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006
Any PTCA procedure | Discharges per 10,000 population
Both sexes:
45 years and over | 51.3 | 46.5 | 54.3 | 59.5 | 52.6 | 52.8 | 58.5 | 58.6 | 58.1 | 54.7 | 55.2
45–64 years | 40.3 | 34.4 | 40.5 | 46.4 | 37.5 | 37.3 | 41.6 | 39.9 | 40.0 | 38.4 | 39.7
65 years and over | 68.9 | 66.4 | 77.3 | 81.9 | 79.6 | 81.0 | 90.1 | 94.6 | 93.3 | 87.0 | 86.2
Men:
45 years and over | 74.4 | 66.5 | 74.7 | 84.0 | 72.8 | 74.5 | 82.9 | 81.2 | 81.9 | 80.6 | 76.6
45–64 years | 62.2 | 53.5 | 61.0 | 69.1 | 55.9 | 55.0 | 61.2 | 59.8 | 59.8 | 59.4 | 58.2
65 years and over | 97.4 | 91.5 | 101.5 | 114.1 | 108.3 | 116.3 | 130.6 | 129.1 | 132.0 | 129.4 | 119.7
Women:
45 years and over | 31.9 | 29.7 | 37.0 | 38.6 | 35.5 | 34.3 | 37.6 | 39.2 | 37.5 | 32.2 | 36.5
45–64 years | 19.7 | 16.4 | 21.3 | 25.1 | 20.0 | 20.5 | 23.1 | 20.9 | 21.2 | 18.3 | 22.2
65 years and over | 48.9 | 48.7 | 60.1 | 59.0 | 59.6 | 56.2 | 61.4 | 69.9 | 65.5 | 56.4 | 61.9
PTCA without stent
Both sexes:
45 years and over | 32.5 | 23.3 | 16.7 | 14.5 | 9.4 | 8.7 | 10.3 | 9.4 | 6.4 | 5.1 | 5.3
45–64 years | 24.9 | 16.3 | 11.6 | 10.6 | 6.8 | 5.8 | 7.9 | 5.7 | 4.1 | 3.1 | 3.6
65 years and over | 44.5 | 34.8 | *25.1 | 21.2 | 14.0 | 14.2 | 14.8 | 16.5 | 11.0 | 9.0 | 8.8
Men:
45 years and over | 45.2 | 32.3 | 23.1 | 20.4 | 13.7 | 12.7 | 13.1 | 11.9 | 8.8 | 7.1 | 7.1
45–64 years | 36.9 | 25.0 | 17.1 | 15.5 | 10.0 | 8.2 | 10.3 | 8.1 | 5.9 | 4.1 | 5.0
65 years and over | 60.9 | 46.2 | 35.1 | *30.2 | 21.2 | 22.2 | 19.5 | 20.3 | 15.2 | 13.9 | 11.9
Women:
45 years and over. | 21.7 | 15.7 | 11.2 | 9.5 | 5.8 | 5.4 | 7.9 | 7.3 | 4.5 | 3.3 | 3.7
45–64 years | 13.7 | 8.0 | 6.5 | *6.0 | 3.7 | 3.4 | 5.7 | 3.4 | 2.4 | 2.1 | 2.2
65 years and over | 33.0 | 26.9 | *18.1 | 14.8 | 9.0 | 8.5 | 11.5 | *13.8 | 7.9 | 5.4 | 6.5
PTCA with bare stent
Both sexes:
45 years and over | 18.9 | 23.2 | 37.6 | 45.0 | 43.2 | 44.1 | 48.2 | 33.0 | 11.6 | 5.4 | 7.4
45–64 years | 15.4 | 18.2 | 28.9 | 35.8 | 30.7 | 31.5 | 33.7 | 22.6 | 8.2 | 3.3 | 5.4
65 years and over | 24.4 | 31.5 | 52.1 | 60.7 | 65.6 | 66.9 | 75.3 | 52.8 | 18.3 | 9.7 | 11.3
Men:
45 years and over | 29.2 | 34.2 | 51.5 | 63.7 | 59.2 | 61.8 | 69.8 | 46.1 | 17.6 | 7.7 | 10.2
45–64 years | 25.4 | 28.5 | 43.9 | 53.6 | 45.9 | 46.8 | 51.0 | 33.9 | 12.5 | 5.2 | 7.7
65 years and over | 36.4 | 45.2 | 66.5 | 83.9 | 87.0 | 94.1 | 111.1 | 73.5 | 29.1 | 13.6 | 15.8
Women:
45 years and over | 10.2 | 14.0 | 25.8 | 29.1 | 29.7 | 28.9 | 29.7 | 21.7 | 6.4 | 3.4 | 5.0
45–64 years | 6.1 | 8.5 | 14.8 | 19.1 | 16.3 | 17.1 | 17.4 | 12.0 | 4.0 | 1.5 | *3.2
65 years and over | 15.9 | 21.9 | 42.0 | 44.2 | 50.6 | 47.7 | 49.9 | 38.0 | 10.5 | 6.9 | 8.1
PTCA with drug-eluting stent
Both sexes:
45 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 16.3 | 40.0 | 44.2 | 42.5
45–64 years | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 11.6 | 27.7 | 32.0 | 30.7
65 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 25.3 | 64.0 | 68.3 | 66.1
Men:
45 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 23.3 | 55.5 | 65.8 | 59.4
45–64 years | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 17.9 | 41.4 | 50.1 | 45.4
65 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 35.3 | 87.7 | 101.9 | 92.0
Women:
45 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 10.2 | 26.6 | 25.5 | 27.8
45–64 years | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 5.5 | 14.7 | 14.8 | 16.8
65 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 18.1 | 47.0 | 44.1 | 47.3
Any PTCA procedure | Standard error
Both sexes:
45 years and over | 4.8 | 4.0 | 5.0 | 4.8 | 4.2 | 4.0 | 4.3 | 5.3 | 4.5 | 4.2 | 3.9
45–64 years | 3.6 | 2.9 | 3.9 | 4.4 | 2.8 | 2.9 | 3.2 | 3.5 | 3.3 | 3.0 | 3.1
65 years and over | 7.3 | 6.4 | 7.7 | 6.6 | 7.4 | 6.9 | 7.5 | 9.5 | 7.6 | 6.9 | 6.2
Men:
45 years and over | 6.9 | 5.7 | 6.7 | 6.9 | 6.0 | 5.8 | 6.1 | 7.3 | 6.2 | 6.5 | 5.7
45–64 years | 5.5 | 5.0 | 6.2 | 6.1 | 4.6 | 4.5 | 4.9 | 5.1 | 4.9 | 4.6 | 4.8
65 years and over | 11.1 | 8.5 | 9.5 | 10.5 | 10.5 | 10.2 | 11.7 | 13.8 | 10.8 | 12.0 | 9.0
Women:
45 years and over | 3.4 | 2.9 | 3.8 | 3.3 | 2.9 | 3.0 | 3.1 | 4.1 | 3.3 | 2.6 | 2.8
45–64 years | 2.5 | 1.7 | 2.4 | 3.2 | 1.7 | 1.7 | 2.3 | 2.8 | 2.1 | 1.9 | 2.0
65 years and over | 5.4 | 5.4 | 7.0 | 5.0 | 5.9 | 5.9 | 5.6 | 7.4 | 6.0 | 4.5 | 5.0
PTCA without stent
Both sexes:
45 years and over | 3.7 | 2.9 | 3.0 | 2.6 | 1.1 | 1.0 | 1.2 | 1.3 | 0.8 | 0.5 | 0.6
45–64 years | 2.7 | 1.9 | 1.8 | 1.9 | 1.0 | 0.7 | 0.9 | 0.8 | 0.5 | 0.4 | 0.5
65 years and over | 5.6 | 4.7 | 5.2 | 4.0 | 1.7 | 1.9 | 2.1 | 2.9 | 1.5 | 1.0 | 1.2
Men:
45 years and over | 5.2 | 4.1 | 4.0 | 3.9 | 1.8 | 1.4 | 1.5 | 1.7 | 1.0 | 0.8 | 1.1
45–64 years | 4.1 | 3.3 | 2.9 | 2.7 | 1.6 | 1.1 | 1.4 | 1.1 | 0.8 | 0.6 | 0.8
65 years and over | 8.7 | 6.5 | 6.9 | 6.9 | 3.2 | 3.0 | 2.9 | 3.7 | 2.2 | 1.9 | 2.3
Women:
45 years and over | 2.8 | 1.9 | 2.2 | 1.6 | 0.7 | 0.8 | 1.1 | 1.2 | 0.7 | 0.5 | 0.5
45–64 years | 2.1 | 1.0 | 1.1 | 1.4 | 0.6 | 0.6 | 0.8 | 0.6 | 0.5 | 0.5 | 0.4
65 years and over | 4.5 | 3.8 | 4.2 | 2.4 | 1.2 | 1.5 | 2.0 | 2.8 | 1.4 | 0.8 | 1.0
PTCA with bare stent
Both sexes:
45 years and over | 1.8 | 2.3 | 3.5 | 3.9 | 3.7 | 3.4 | 3.6 | 2.9 | 1.6 | 0.7 | 0.9
45–64 years | 1.6 | 1.8 | 2.9 | 3.6 | 2.2 | 2.5 | 2.7 | 2.0 | 1.1 | 0.5 | 0.8
65 years and over | 2.7 | 3.5 | 5.1 | 5.4 | 6.9 | 5.9 | 6.4 | 5.3 | 2.7 | 1.4 | 1.3
Men:
45 years and over | 2.9 | 3.3 | 4.6 | 5.3 | 5.2 | 5.0 | 5.3 | 4.1 | 2.5 | 1.1 | 1.3
45–64 years | 2.7 | 2.9 | 4.7 | 5.3 | 3.7 | 4.1 | 4.0 | 3.0 | 1.8 | 0.9 | 1.2
65 years and over | 4.8 | 5.0 | 6.1 | 7.3 | 9.4 | 8.4 | 10.4 | 7.9 | 4.5 | 2.2 | 1.9
Women:
45 years and over | 1.2 | 1.7 | 2.7 | 2.9 | 2.6 | 2.7 | 2.4 | 2.4 | 1.0 | 0.5 | 0.8
45–64 years | 1.0 | 1.2 | 1.7 | 2.5 | 1.4 | 1.5 | 1.9 | 1.8 | 0.7 | 0.3 | 0.7
65 years and over | 1.8 | 2.9 | 5.1 | 4.8 | 5.7 | 5.4 | 4.4 | 4.5 | 1.8 | 1.2 | 1.3
PTCA with drug-eluting stent | Standard error
Both sexes:
45 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 1.8 | 3.5 | 3.8 | 3.2
45–64 years | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 1.3 | 2.8 | 2.8 | 2.7
65 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 3.0 | 5.2 | 6.1 | 4.8
Men:
45 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 2.6 | 4.6 | 5.9 | 4.6
45–64 years | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 2.0 | 4.0 | 4.2 | 4.4
65 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 4.7 | 7.2 | 10.8 | 6.8
Women:
45 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 1.3 | 2.7 | 2.3 | 2.3
45–64 years | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 1.1 | 1.9 | 1.7 | 1.7
65 years and over | . . . | . . . | . . . | . . . | . . . | . . . | . . . | 2.6 | 4.7 | 3.9 | 4.2

PTCA is percutaneous transluminal coronary angioplasty

. . . Category not applicable.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: Rates are based on the civilian population. PTCA discharges for 1996–2005 include International Classification of Diseases, ninth revision, Clinical Modification (ICD–9–CM) codes 36.01 or 36.02 or 36.05; 2006 data are based on the new code 00.66. PTCA discharges without the insertion of a coronary stent include a PTCA code but do not include codes 36.06 and 36.07. PTCA discharges with the insertion of a bare coronary stent include a PTCA code and 36.06 but not 36.07. PTCA discharges with the insertion of a drug-eluting coronary stent include a PTCA code and 36.07 but not 36.06. The code 36.07 was introduced in 2003.

SOURCE: CDC/NCHS, National Hospital Discharge Survey.

Data table for Figures 29A and 29B Cholecystectomy procedures among adults 18 years of age and over, by location of care, type of procedure, sex, and age: United States, 1996 and 2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig29.xls) Click here for Powerpoint slide 29A (http://www.cdc.gov/nchs/ppt/hus/HUS09fig29a.ppt) Click here for Powerpoint slide 29B (http://www.cdc.gov/nchs/ppt/hus/HUS09fig29b.ppt)

NOTE: See Chartbook Figure 29A and Figure 29B for Table 29

| Hospital discharges | | | | Ambulatory surgery visits
Type of procedure, sex, and age | 1996 | SE | 2006 | SE | 1996 | SE | 2006 | SE
Any cholecystectomy procedure | Number per 10,000 population
Both sexes:
18 years and over | 22.3 | 1.1 | 18.1 | 0.9 | 16.1 | 1.4 | 21.2 | 2.0
18–44 years | 12.2 | 0.8 | 13.3 | 0.9 | 13.5 | 1.3 | 19.5 | 2.5
45 years and over | 35.2 | 2.0 | 22.9 | 1.2 | 19.3 | 1.8 | 23.0 | 2.5
Men:
18 years and over | 14.8 | 1.0 | 12.2 | 0.8 | 7.1 | 0.7 | 7.5 | 1.0
18–44 years | 4.2 | 0.5 | 5.7 | 0.6 | 4.5 | 0.6 | *5.1 | 1.2
45 years and over | 29.4 | 2.1 | 19.3 | 1.4 | 10.6 | 1.3 | 10.1 | 1.6
Women:
18 years and over | 29.3 | 1.6 | 23.6 | 1.2 | 24.4 | 2.2 | 34.2 | 3.7
18–44 years | 20.2 | 1.5 | 21.0 | 1.5 | 22.4 | 2.2 | 34.1 | 4.8
45 years and over | 40.0 | 2.6 | 26.0 | 1.5 | 26.7 | 2.8 | 34.2 | 4.4
Laparoscopic cholecystectomy procedure
Both sexes:
18 years and over | 15.3 | 0.9 | 14.0 | 0.7 | 16.0 | 1.4 | 21.2 | 2.0
18–44 years | 9.7 | 0.7 | 11.5 | 0.8 | 13.4 | 1.3 | 19.5 | 2.5
45 years and over | 22.4 | 1.6 | 16.6 | 0.9 | 19.3 | 1.8 | 22.9 | 2.5
Men:
18 years and over | 8.4 | 0.6 | 8.8 | 0.6 | 7.0 | 0.7 | 7.3 | 1.0
18–44 years | 3.2 | 0.4 | 4.6 | 0.5 | 4.5 | 0.6 | *5.1 | 1.2
45 years and over | 15.7 | 1.2 | 13.3 | 1.1 | 10.6 | 1.3 | 9.8 | 1.6
Women:
18 years and over | 21.6 | 1.5 | 19.0 | 1.0 | 24.3 | 2.2 | 34.2 | 3.7
18–44 years | 16.1 | 1.3 | 18.5 | 1.4 | 22.3 | 2.2 | 34.1 | 4.8
45 years and over | 28.0 | 2.3 | 19.4 | 1.2 | 26.7 | 2.8 | 34.2 | 4.4

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: Cholecystectomy is gallbladder removal. Rates are based on the civilian population as of July 1. Discharges are from nonfederal short-stay hospitals. Visits are to hospital-based and freestanding ambulatory surgery centers. To avoid double counting, visits that resulted in a hospital admission are excluded. Rates are for at least one procedure listed. Cholecystectomy is International Classification of Diseases, ninth revision, Clinical Modification (ICD–9–CM) procedure code 51.2. Laparoscopic cholecystectomy (laparoscopic cholecystectomy and laparoscopic partial cholecystectomy) is procedure code 51.23 or 51.24 and is a subset of cholecystectomy.

SOURCE: CDC/NCHS, National Hospital Discharge Survey and National Survey of Ambulatory Surgery.

Data table for Figure 30 Upper endoscopy or colonoscopy procedures among adults 18 years of age and over, by location of care, type of procedure, and age: United States, 1996 and 2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig30.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig30.ppt)

NOTE: See Chartbook Figure for Table 30

| Ambulatory surgery visit | | | | Hospital discharges
| 1996 | | 2006 | | 1996 | | 2006
Type of procedure and age | Rate | SE | Rate | SE | Rate | SE | Rate | SE
Upper endoscopy (EGD) | Number of procedures per 10,000 population
18 years of age and over | 76.8 | 6.3 | 146.6 | 13.3 | 40.6 | 1.8 | 44.2 | 2.1
18–44 years | 36.6 | 3.4 | 64.9 | 8.1 | 11.2 | 0.8 | 12.8 | 0.8
45–54 years | 81.2 | 7.4 | 153.8 | 15.9 | 29.2 | 2.5 | 31.1 | 2.2
45–64 years. | 93.7 | 8.2 | 183.1 | 18.1 | 38.2 | 2.5 | 39.6 | 2.2
65 years and over | 181.3 | 16.1 | 319.8 | 28.8 | 140.3 | 6.7 | 148.4 | 7.5
65–74 years | 170.8 | 15.3 | 340.5 | 32.6 | 91.0 | 5.6 | 105.7 | 6.2
75 years and over | 194.3 | 18.3 | 298.4 | 29.4 | 200.8 | 9.8 | 192.5 | 10.8
75–84 years | 201.0 | 20.0 | 350.8 | 36.9 | 180.4 | 9.8 | 170.7 | 10.7
85 years and over | 173.7 | 19.9 | 169.3 | 28.4 | 262.8 | 17.8 | 246.1 | 16.7
Colonoscopy
18 years of age and over | 80.1 | 5.8 | 248.9 | 28.1 | 20.2 | 0.9 | 20.8 | 1.0
18–44 years | 28.7 | 3.1 | 66.6 | 11.3 | 4.4 | 0.4 | 5.1 | 0.4
45–54 years | 83.4 | 6.9 | 327.1 | 37.8 | 11.0 | 1.1 | 14.5 | 1.1
45–64 years | 105.8 | 7.8 | 383.4 | 42.2 | 16.6 | 1.1 | 18.7 | 1.2
65 years and over | 207.0 | 16.5 | 529.1 | 62.1 | 77.5 | 3.8 | 72.4 | 4.1
65–74 years | 216.1 | 17.0 | 637.1 | 84.9 | 50.0 | 3.5 | 48.6 | 3.4
75 years and over | 195.8 | 19.1 | 417.6 | 46.5 | 111.2 | 6.3 | 96.9 | 6.1
75–84 years | 228.5 | 22.1 | 516.7 | 60.5 | 97.4 | 6.1 | 88.7 | 6.3
85 years and over | 96.7 | 13.9 | 173.6 | 29.2 | 153.1 | 16.1 | 117.3 | 9.9

SE is standard error; EGD is esophagogastroduodenoscopy.

NOTES: Rates are based on the civilian population as of July 1. Discharges are from nonfederal short-stay hospitals. Visits are to hospital-based and freestanding ambulatory surgery centers. To avoid double counting, visits that resulted in a hospital admission are excluded. Rates are for at least one procedure listed. EGD is International Classification of Diseases, ninth revision, Clinical Modification (ICD–9–CM) procedure codes 45.13 or 45.16, and colonoscopy is codes 45.23 or 45.25. (See Appendix II, International Classification of Diseases, ninth revision, Clinical Modification. Also see Tables 103 and XI.)

SOURCES: CDC/NCHS, National Hospital Discharge Survey and National Survey of Ambulatory Surgery.

Data table for Figure 31 Medicare decedents 65 years of age and over with an ICU/CCU stay in the last 6 months of life, by state: United States, 2005

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig31.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig31.ppt)

NOTE: See Chartbook Figure for Table 31

State | ICU/CCU admissions during last 6 months of life per 1,000 decedents | Percent of decedents admitted to ICU/CCU at least once during last 6 months of life | State | ICU/CCU admissions during last 6 months of life per 1,000 decedents | Percent of decedents admitted to ICU/CCU at least once during last 6 months of life
United States | 556.62 | 39 | Missouri | 567.49 | 40
Alabama | 507.94 | 38 | Montana | 362.06 | 28
Alaska | 403.84 | 30 | Nebraska | 442.01 | 32
Arizona | 622.07 | 42 | Nevada | 605.76 | 44
Arkansas | 472.73 | 35 | New Hampshire | 329.86 | 26
California | 680.42 | 45 | New Jersey | 767.78 | 49
Colorado | 409.32 | 32 | New Mexico | 451.12 | 33
Connecticut | 448.10 | 33 | New York | 436.67 | 34
Delaware | 557.98 | 41 | North Carolina | 523.59 | 38
District of Columbia | 515.73 | 39 | North Dakota | 295.82 | 23
Florida | 753.23 | 49 | Ohio | 581.12 | 40
Georgia | 528.54 | 39 | Oklahoma | 448.49 | 34
Hawaii | 465.42 | 36 | Oregon | 340.70 | 26
Idaho | 317.05 | 25 | Pennsylvania | 634.39 | 43
Illinois | 687.93 | 45 | Rhode Island | 376.51 | 29
Indiana | 542.94 | 39 | South Carolina | 567.16 | 41
Iowa | 345.13 | 26 | South Dakota | 360.72 | 28
Kansas | 414.05 | 31 | Tennessee | 544.15 | 39
Kentucky | 561.81 | 39 | Texas | 639.43 | 44
Louisiana | 545.98 | 39 | Utah | 373.80 | 28
Maine | 346.97 | 27 | Vermont | 284.06 | 23
Maryland | 540.40 | 38 | Virginia | 536.26 | 39
Massachusetts | 408.93 | 31 | Washington | 460.71 | 34
Michigan | 568.08 | 40 | West Virginia | 547.67 | 39
Minnesota | 409.93 | 30 | Wisconsin | 358.36 | 27
Mississippi | 428.59 | 33 | Wyoming | 362.52 | 28

ICU/CCU care includes care provided in medical, surgical, trauma, burn, or other types of critical care units.

NOTES: Excludes Medicare enrollees who were members of a health maintenance organization (HMO). Geographic location is based on decedent’s residence, not place of care. This analysis is for decedents 65–99 years of age at the time of death.

SOURCE: Dartmouth Atlas of Health Care. Available from: http://www.dartmouthatlas.org/.

Data table for Figure 32 Selected solid organ transplantation, by type of organ: United States, 1997–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig32.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig32.ppt)

NOTE: See Chartbook Figure for Table 32

Type of organ | 1997 | 1998 | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006
| Incidence of transplants per 1 million population
Kidney | 43.70 | 46.08 | 46.79 | 48.23 | 50.00 | 51.25 | 52.05 | 54.51 | 55.60 | 57.15
Liver | 15.64 | 16.71 | 17.42 | 17.70 | 18.19 | 18.49 | 19.51 | 21.01 | 21.73 | 22.23
Heart | 8.56 | 8.69 | 8.02 | 7.79 | 7.72 | 7.47 | 7.07 | 6.86 | 7.17 | 7.33
Lung | 3.48 | 3.22 | 3.27 | 3.40 | 3.71 | 3.61 | 3.73 | 3.99 | 4.74 | 4.70
Kidney-pancreas | 3.19 | 3.60 | 3.45 | 3.24 | 3.12 | 3.14 | 3.00 | 3.00 | 3.05 | 3.09
Multi-organ | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - -
Pancreas after kidney | 0.49 | 0.58 | 0.81 | 1.08 | 1.07 | 1.30 | 1.18 | 1.43 | 1.16 | 0.98
Pancreas transplant alone | 0.30 | 0.33 | 0.51 | 0.47 | 0.59 | 0.62 | 0.54 | 0.62 | 0.67 | 0.57
Intestine | 0.25 | 0.26 | 0.27 | 0.29 | 0.39 | 0.37 | 0.40 | 0.52 | 0.59 | 0.58
Heart-lung | 0.23 | 0.17 | 0.19 | 0.17 | 0.09 | 0.11 | 0.10 | 0.14 | 0.12 | 0.10
| Number of transplants
Total | 20,093 | 21,319 | 21,826 | 23,012 | 23,947 | 24,552 | 25,088 | 26,542 | 27,530 | 28,291
Kidney | 11,561 | 12,318 | 12,633 | 13,446 | 14,102 | 14,526 | 14,857 | 15,674 | 16,076 | 16,646
Liver | 4,014 | 4,369 | 4,605 | 4,807 | 4,985 | 5,059 | 5,365 | 5,781 | 6,000 | 6,136
Heart | 2,266 | 2,310 | 2,157 | 2,167 | 2,171 | 2,112 | 2,026 | 1,960 | 2,062 | 2,147
Lung | 929 | 866 | 892 | 958 | 1,059 | 1,041 | 1,080 | 1,168 | 1,403 | 1,401
Kidney-pancreas | 847 | 969 | 937 | 914 | 889 | 902 | 869 | 880 | 896 | 914
Multi-organ | 197 | 184 | 175 | 222 | 238 | 322 | 350 | 441 | 519 | 566
Pancreas after kidney | 130 | 156 | 220 | 304 | 304 | 374 | 344 | 419 | 343 | 292
Pancreas transplant alone | 64 | 73 | 125 | 118 | 130 | 142 | 116 | 129 | 129 | 98
Intestine | 23 | 28 | 31 | 30 | 42 | 42 | 53 | 52 | 68 | 60
Heart-lung | 62 | 46 | 51 | 46 | 27 | 32 | 28 | 38 | 34 | 31

- - - Data not available.

NOTES: An organ that is divided into segments (liver, lung, pancreas, intestine) is counted once per transplant. Kidney-pancreas and heart-lung transplants are counted as one transplant. Other multiple organ transplants are counted only in the multi-organ category.

SOURCE: Organ Procurement and Transplantation Network, Scientific Registry of Transplant Recipients (OPTN/SRTR), 2007 annual report. Data as of May 1, 2007.

Data table for Figure 33 Assisted reproductive technology (ART) cycles initiated among women, by age: United States, 1996–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig33.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig33.ppt)

NOTE: See Chartbook Figure for Table 33

| 1996 | 1997 | 1998 | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006
Age | Number of ART cycles initiated
Total | 64,681 | 72,397 | 81,438 | 87,636 | 99,629 | 107,587 | 115,392 | 122,872 | 127,977 | 134,260 | 138,198
Under 35 years | 28,741 | 30,944 | 34,952 | 37,397 | 41,988 | 45,274 | 47,806 | 50,842 | 52,334 | 53,567 | 54,386
35–37 years | 14,258 | 15,931 | 17,769 | 19,240 | 21,815 | 22,412 | 24,396 | 25,660 | 27,259 | 29,627 | 31,127
38–40 years | 12,143 | 13,830 | 15,271 | 16,489 | 18,733 | 20,710 | 22,356 | 24,006 | 24,725 | 25,401 | 25,933
41 years and over | 9,539 | 11,692 | 13,446 | 14,510 | 17,093 | 19,191 | 20,834 | 22,364 | 23,659 | 25,665 | 26,752
41–42 years | 4,968 | 6,214 | 6,939 | 7,531 | 8,665 | 9,757 | 10,754 | 11,446 | 11,934 | 12,951 | 13,204
43 years and over | 4,571 | 5,478 | 6,507 | 6,979 | 8,428 | 9,434 | 10,080 | 10,918 | 11,725 | 12,714 | 13,548

NOTES: CDC defines ART procedures as those that involve surgically removing eggs from a woman’s ovaries, combining them with sperm in the laboratory, and returning them to the woman’s body or donating them to another woman. ART procedures do not include treatments in which only sperm are handled (i.e., intrauterine or artificial insemination) or procedures in which a woman only takes medicine to stimulate egg production without the intention of having eggs retrieved from the ovaries. ART is more appropriately considered a cycle of treatment rather than a procedure at a single point in time because ART consists of several steps over an interval of approximately 2 weeks. All ART cycles that were intiated, even those that were discontinued before all steps were completed, are included in this analysis. Cycles in which a new type of treatment was being evaluated are excluded.

SOURCE: CDC, National Center for Chronic Disease Prevention and Health Promotion, Division of Reproductive Health.

Data table for Figure 34 Adults 45 years of age and over reporting prescription drug use in the past month for selected drug categories, by sex and age: United States, 1988–1994 and 2003–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig34.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig34.ppt)

NOTE: See Chartbook Figure for Table 34

| Antidiabetic drugs | | | | Statin drugs
| 1988–1994 | | 2003–2006 | | 1988–1994 | | 2003–2006
Sex and age | Percent | SE | Percent | SE | Percent | SE | Percent | SE
Both sexes:
45 years and over | 6.9 | 0.3 | 10.7 | 0.5 | 2.4 | 0.3 | 22.0 | 0.9
45–64 years | 5.5 | 0.4 | 8.3 | 0.6 | 2.2 | 0.3 | 15.1 | 1.0
65 years and over | 9.0 | 0.6 | 15.3 | 1.0 | 2.8 | 0.5 | 35.4 | 0.9
Men:
45 years and over | 7.0 | 0.5 | 10.1 | 0.7 | 2.3 | 0.3 | 23.6 | 0.9
45–64 years | 5.9 | 0.7 | 7.9 | 0.8 | *2.5 | 0.5 | 16.8 | 1.3
65 years and over | 9.0 | 1.0 | 15.0 | 1.4 | *1.9 | 0.6 | 38.9 | 1.5
Women:
45 years and over | 6.8 | 0.4 | 11.2 | 0.8 | 2.6 | 0.5 | 20.5 | 1.2
45–64 years | 5.1 | 0.4 | 8.7 | 0.8 | *1.9 | 0.4 | 13.5 | 1.4
65 years and over | 9.0 | 0.7 | 15.6 | 1.4 | 3.5 | 0.6 | 32.8 | 1.4

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTES: Data are for the civilian noninstitutionalized population. See Technical Notes for specific drugs.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey.

Data table for Figure 35 Death rates for human immunodeficiency virus (HIV) disease for all ages, by sex and race and Hispanic origin: United States, 1987–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig35.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig35.ppt)

NOTE: See Chartbook Figure for Table 35

Year | Male | Female | White, not Hispanic male | Black male | Hispanic male | White, not Hispanic female | Black female | Hispanic female
| Deaths per 100,000 population
1987 | 10.4 | 1.1 | 10.7 | 26.2 | 18.8 | 0.5 | 4.6 | 2.1
1988 | 12.6 | 1.4 | 11.2 | 32.8 | 21.5 | 0.6 | 6.2 | 3.1
1989 | 16.5 | 1.8 | 12.7 | 42.1 | 28.5 | 0.6 | 8.2 | 4.1
1990 | 18.5 | 2.2 | 14.1 | 46.3 | 28.8 | 0.7 | 10.1 | 3.8
1991 | 21.0 | 2.7 | 15.5 | 55.8 | 31.9 | 0.9 | 12.2 | 4.9
1992 | 23.3 | 3.2 | 16.7 | 65.1 | 35.1 | 1.0 | 14.7 | 5.7
1993 | 25.1 | 3.9 | 17.4 | 73.8 | 35.2 | 1.3 | 17.6 | 6.8
1994 | 27.5 | 4.8 | 18.5 | 86.2 | 41.5 | 1.6 | 22.4 | 8.0
1995 | 27.3 | 5.3 | 17.9 | 89.0 | 40.8 | 1.7 | 24.4 | 8.8
1996 | 19.0 | 4.2 | 11.2 | 70.3 | 28.0 | 1.3 | 20.8 | 6.3
1997 | 9.6 | 2.6 | 4.8 | 40.9 | 14.0 | 0.7 | 13.7 | 3.3
1998 | 7.6 | 2.2 | 3.7 | 33.2 | 10.2 | 0.5 | 12.0 | 2.8
1999 | 8.2 | 2.5 | 4.0 | 36.1 | 10.9 | 0.7 | 13.1 | 3.0
2000 | 7.9 | 2.5 | 3.8 | 35.1 | 10.6 | 0.7 | 13.2 | 2.9
2001 | 7.5 | 2.5 | 3.6 | 33.8 | 9.7 | 0.6 | 13.4 | 2.7
2002 | 7.4 | 2.5 | 3.5 | 33.3 | 9.1 | 0.6 | 13.4 | 2.6
2003 | 7.1 | 2.4 | 3.4 | 31.3 | 9.2 | 0.6 | 12.8 | 2.7
2004 | 6.6 | 2.4 | 3.1 | 29.2 | 8.2 | 0.6 | 13.0 | 2.4
2005 | 6.2 | 2.3 | 3.0 | 28.2 | 7.5 | 0.6 | 12.0 | 1.9
2006 | 5.9 | 2.2 | 2.8 | 26.3 | 7.0 | 0.6 | 12.2 | 1.9

NOTES: Data are age-adjusted. Highly active antiretroviral therapy (HAART) was introduced in 1996. The horizontal rules in the data table around 1995–1997 denote the period from pre-HAART to widespread HAART use. Categories for the coding and classification of HIV disease were introduced in the United States in 1987. For the period 1987–1998, underlying cause of death was coded according to the ninth revision of the International Classification of Diseases (ICD–9). Starting with 1999 data, cause of death is coded according to ICD–10. (See Appendix II, Cause of death; Human immunodeficiency virus disease; Tables IV and V.) Age-adjusted rates are calculated using the year 2000 standard population. The black race group may include persons of Hispanic origin. Persons of Hispanic origin may be of any race. (See Appendix II, Age adjustment; Hispanic origin.) Rates are based on the resident population. (Also see Table 38.)

SOURCE: CDC/NCHS, National Vital Statistics System.

Data table for Figure 36 Costs and number of discharges for hospital stays with the six most expensive principal procedures, United States: 1999–2006

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus09figures/fig36.xls) Click here for Powerpoint (http://www.cdc.gov/nchs/ppt/hus/HUS09fig36.ppt)

NOTE: See Chartbook Figure for Table 36

Selected principal procedure | 1999 | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006
| Amount in millions (2006 dollars)
Respiratory intubation and mechanical ventilation | $10,687 | $11,424 | $12,011 | $13,184 | $14,356 | $15,198 | $15,514 | $15,729
Percutaneous transluminal coronary angioplasty (PTCA) | 6,407 | 8,161 | 9,268 | 9,797 | 10,331 | 11,946 | 12,559 | 13,327
Cardiac pacemaker, cardioverter, or defibrillator | 3,518 | 4,238 | 5,102 | 6,498 | 7,521 | 7,983 | 7,937 | 8,693
Coronary artery bypass graft (CABG) | 8,344 | 10,055 | 9,731 | 9,265 | 9,285 | 8,231 | 7,872 | 8,085
Knee arthroplasty (knee replacement) | 3,573 | 4,135 | 4,608 | 5,187 | 5,760 | 6,751 | 7,787 | 7,920
Spinal fusion | 2,651 | 3,394 | 4,045 | 4,916 | 5,862 | 6,330 | 7,475 | 7,670
| Standard errors for amounts in millions (2006 dollars)
Respiratory intubation and mechanical ventilation | $368 | $425 | $415 | $472 | $523 | $507 | $524 | $463
Percutaneous transluminal coronary angioplasty (PTCA) | 466 | 514 | 597 | 647 | 607 | 808 | 788 | 837
Cardiac pacemaker, cardioverter, or defibrillator | 190 | 180 | 271 | 368 | 405 | 478 | 453 | 540
Coronary artery bypass graft (CABG) | 586 | 613 | 590 | 572 | 555 | 487 | 519 | 507
Knee arthroplasty (knee replacement) | 166 | 149 | 202 | 269 | 206 | 306 | 317 | 294
Spinal fusion | 167 | 187 | 222 | 189 | 372 | 358 | 498 | 434
| Number of discharges
Respiratory intubation and mechanical ventilation | 547,580 | 528,242 | 542,971 | 585,501 | 616,788 | 676,430 | 667,264 | 712,049
Percutaneous transluminal coronary angioplasty (PTCA) | 501,510 | 601,832 | 701,981 | 692,621 | 675,673 | 720,927 | 749,577 | 828,319
Cardiac pacemaker, cardioverter, or defibrillator | 215,017 | 232,779 | 267,316 | 294,704 | 308,300 | 316,787 | 325,250 | 353,116
Coronary artery bypass graft (CABG) | 323,753 | 349,967 | 344,210 | 316,471 | 291,095 | 255,609 | 227,774 | 245,231
Knee arthroplasty (knee replacement) | 311,106 | 328,122 | 363,536 | 399,139 | 427,255 | 481,452 | 549,867 | 547,364
Spinal fusion | 188,309 | 210,682 | 252,400 | 276,984 | 297,883 | 303,374 | 332,159 | 343,307

NOTES: Costs were derived from total hospital charges (the amount the hospital billed for the hospital stay) using cost-to-charge ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services. For each hospital, a hospital-wide cost-to-charge ratio was used to transform charges into costs. Costs tend to reflect the actual costs to produce hospital services, whereas charges represent what the hospital billed for the care. The hospital costs do not include the professional billing (physician fees). The costs shown were for the entire hospital stay, not just the costs of performing the principal procedure. Costs were adjusted to 2006 dollars using the Gross Domestic Product Price Index. Procedures were classified according to the Clinical Classification Software (CCS) procedure group number. CCS codes were as follows: respiratory intubation and mechanical ventilation (216); PTCA (45); CABG (44); cardiac pacemaker, cardioverter, defibrillator (48); spinal fusion (158); knee arthroplasty (152).

SOURCE: Agency for Healthcare Research and Quality, Healthcare Cost & Utilization Project, Nationwide Inpatient Sample.