# Appendix III Additional Data Years Available

For trend tables spanning long periods, only selected data years are shown in Health, United States, to highlight major trends. Additional years of data for some of the tables are available in electronic spreadsheets on the Health, United States, 2009 website at http://www.cdc.gov/nchs/hus.htm. Standard errors are included in spreadsheet files for trend tables that are based on the National Health Interview Survey (NHIS), the National Health and Nutrition Examination Survey (NHANES), and the National Survey of Family Growth (NSFG).

Table number | Table topic | Additional data years available
1 | Resident population | 2001–2004
2 | Inmates in state or federal prisons and local jails | 2001–2003
3 | Poverty | 1986–1989, 1991–1994, 1996–1999, 2001–2003, 2005
4 | Fertility rates and birth rates | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004
5 | Live births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004
6 | Twin births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996, 1998–1999, 2001–2003
7 | Prenatal care | 1975, 1981–1989, 1991–1999, 2001–2002
8 | Teenage childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2002
9 | Nonmarital childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2002
10 | Maternal smoking | 1991–1994, 1996–1999, 2001
11 | Low birthweight | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001–2003
12 | Low birthweight | 1991–1994, 1996–1999, 2001
14 | Abortions | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001–2002
17 | Infant mortality rates | 1996–1999, 2001–2002; (3 year data: 1996–1998, 1997–1999, 1998–2000, 2000–2002, 2001–2003, 2002–2004)
18 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001–2002
19 | Infant mortality rates | 1981–1989, 1991–1994, 1996–1999
22 | International mortality rates and rankings | 2001, 2002–2004; ranking 2005
23 | International life expectancy | 1999, 2001, 2003–2004
24 | Life expectancy | 1975, 1981–1989, 1991–1994, 1996–1997
26 | Age-adjusted death rates for selected causes | 1981–1989, 1991–1999, 2001–2003
27 | Years of potential life lost | 1991–1999 2001, crude 1999–2003
30 | Urbanization level | 2002–2004, 2003–2005
31 | Death rates for all causes | 1981–1989, 1991–1999, 2001–2004
32 | Diseases of heart | 1981–1989, 1991–1999, 2001–2004
33 | Cerebrovascular diseases | 1981–1989, 1991–1999, 2001–2004
34 | Malignant neoplasms | 1981–1989, 1991–1999, 2001–2004
35 | Malignant neoplasms of trachea, bronchus, and lung | 1981–1989, 1991–1999, 2001–2004
36 | Malignant neoplasm of breast | 1981–1989, 1991–1999, 2001–2004
37 | Chronic lower respiratory diseases | 1981–1989, 1991–1994, 1996–1999, 2001
38 | Human immunodeficiency virus (HIV) disease | 1988–1989, 1991–1994, 2001–2003
39 | Maternal mortality | 1981–1989, 1991–1999, 2001–2003
40 | Motor vehicle-related injuries | 1981–1989, 1991–1999, 2001–2004
41 | Homicide | 1981–1989, 1991–1999, 2001–2004
42 | Suicide | 1981–1989, 1991–1999, 2001–2004
43 | Firearm-related injuries | 1981–1989, 1991–1994, 1996–1999, 2001–2003
44 | Occupational diseases | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2003
46 | Nonfatal occupational injuries and illnesses | 2004
47 | Notifiable diseases | 1985, 1988–1989, 1991–1999, 2001–2004
49 | Cancer incidence rates | 1991–1994, 1996–1999
50 | Five-year relative cancer survival rates | 1978–1980, 1984–1986, 1990–1992
51 | Diabetes | 2001–2004,
53 | Severe headache or migraine, low back pain, and neck pain | 1998–2005
54 | Joint pain | 2003–2005
55 | Basic actions difficulty and complex activity limitation | 1999–2002
56 | Vision and hearing limitations | 1998–1999, 2001–2005
57 | Respondent-assessed health status | 1998–1999, 2001–2002
58 | Serious psychological distress | 1998–1999, 2000–2001, 2002–2003, 2003–2004, 2005–2006
60 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001–2003
61 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001–2003
62 | Cigarette smoking | 1993–1995, 1994–1997, 2002–2004, 2003–2005, 2004–2006
63 | Use of selected substances | 2003–2005
64 | Use of selected substances | 1981–1984, 1986–1989, 1992–1994, 1996–1999, 2001–2004
65 | Lifetime alcohol drinking status | 1998–1999, 2001–2005
66 | Heavier drinking and drinking five or more drinks in a day | 1998–1999, 2001–2004
68 | Hypertension (elevated blood pressure) | 2001–2004
69 | Serum total cholesterol levels | 2001–2004
71 | Leisure-time physical activity | 1999–2005
72 | Overweight, obesity, and healthy weight | 2001–2004
73 | Overweight among children and adolescents | 2001–2004
74 | Untreated dental caries | 1999–2000, 1999–2002
75 | No usual source of health care | 1995–1996, 1997–1998, 1999–2000, 2001–2002, 2004–2005, 2005–2006
76 | No usual source of health care | 2004–2005, 2005–2006
77 | Reduced access to medical care | 1998–2005
78 | Reduced access to medical care | 2000–2001, 2004–2005; 2005–2006
79 | No heath care visits | 1999–2000, 2003–2004, 2004–2005, 2005–2006
80 | Health care visits | 1998–2005
82 | Vaccinations | 1996–1999, 2001–2002
84 | Influenza vaccination | 1991, 1993–1994, 1997–1999, 2001–2002
85 | Pneumococcal vaccination | 1991, 1993–1994, 1997–1999, 2001–2002
86 | Mammography | 1991, 1998
87 | Pap smears | 1998
88 | Emergency department visits for children | 1998–2005
89 | Emergency department visits for adults | 1998–1999, 2001–2005
90 | Injury-related visits to hospital emergency departments | 2005–2006
91 | Ambulatory care visits | 1997–1999, 2001–2005
92 | Ambulatory care visits | 1997–1999, 2001–2006
93 | Dental visits | 1998–2005
95 | Prescription drug use | 1999–2000, 1999–2002, 2001–2004
96 | Dietary supplement use | 2001–2004
97 | Additions to mental health organizations | 1992, 1994, 1998, 2000
98 | Discharges | 1998–2005
99 | Discharges | 1991–1994, 1996–1999, 2001–2003
100 | Discharges | 1991–1999, 2001–2005
101 | Discharge rate | 1991–1999, 2001–2005
102 | Average length of stay | 1991–1999, 2001–2005
103 | Discharges | 1991–1999, 2001–2005
105 | Nursing home residents | 1997
106 | Persons employed in health service sites | 2001
107 | Active physicians and doctors of medicine | 2003–2006
108 | Physicians | 1970, 1980, 1987, 1989–1990, 1992–1994, 1996–1999, 2001–2003
109 | Primary care doctors of medicine | 1994, 1996–1999, 2001, 2003–2005
111 | Employees and wages | 2000–2001, 2003–2004, 2006
116 | Mental health organizations | 1992
119 | Nursing homes | 1996–1999, 2001–2006
120 | Medicare-certified providers and suppliers | 1997–1998, 2002, 2004, 2006
121 | Magnetic Resonance Imaging (MRI) units and Computed Tomography (CT) scanners | 2001–2002
122 | Total health expenditures as a percent of gross domestic product | 1961–1969, 1971–1979, 1981–1989, 1991–1994, 1996–1999
129 | Expenditures for mental health services | 1987–1989, 1991–1994, 1996–1999, 2001
130 | Expenditures for substance abuse treatment | 1987–1989, 1991–1994, 1996–1999, 2001
131 | Expenditures for health care | 1998–1999, 2001–2005
132 | Sources of payment for health care | 1996, 1998–1999, 2001–2005
133 | Out-of-pocket health care expenses | 1998–1999, 2001–2002
135 | Employers’ costs and health insurance | 1992–1993, 1995, 1997–1999, 2001–2004
137 | Private health insurance | 1994, 1996, 1998–1999, 2001–2002
138 | Private health insurance | 1994, 1996, 1998–1999, 2001–2002
139 | Medicaid coverage | 1994, 1996, 1998–1999, 2001–2003
140 | No health insurance coverage | 1994, 1996, 1998–1999, 2001–2003
141 | Health care coverage | 1993–1994, 1996–1999, 2001–2005
143 | Medicare | 1996–1998, 2001, 2003
144 | Medicare | All: 1999–2002; 1993–2003
145 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1999, 2001–2002
146 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1999, 2001–2002
147 | Department of Veterans Affairs | 1985, 1988–1989, 1991–1994, 1996–1999, 2001–2004
148 | Medicare | 1995–2006
149 | Medicaid | 1998, 2000–2001, 2003–2005
150 | Persons without health insurance coverage | 2004–2006