# Appendix III Additional Data Years Available

For trend tables spanning long periods, only selected data years are shown to highlight major trends. Additional years of data are available for some of the tables in electronic spreadsheets available through the Internet and on CD-ROM.

To access spreadsheet files on the Internet, go to the Health, United States website at http://www.cdc.gov/nchs/hus.htm, scroll down to “Spreadsheet Files,” and click on 2008 Edition. Downloadable spreadsheet files for trend tables, many of which include more data years than are shown in the printed report, are available in Excel. Standard errors are included in spreadsheet files for trend tables based on the National Health Interview Survey (NHIS), National Health and Nutrition Examination Survey (NHANES), and National Survey of Family Growth (NSFG).

Spreadsheet files in Excel are also available on a CD-ROM. A limited supply of CD-ROMs are available from the National Center for Health Statistics upon request, while supplies last, or CD-ROMs may be purchased from the Government Printing Office.

Table number | Table topic | Additional data years available
1 | Resident population | 2001–2003
2 | Inmates in state or federal prisons and local jails | 2001–2003
3 | Poverty | 1986–1989, 1991–1994, 1996–1999, 2001–2003
4 | Fertility rates and birth rates | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2002
5 | Live births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2003
6 | Twin births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996, 1998–1999, 2001–2002
7 | Prenatal care | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
9 | Teenage childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
10 | Nonmarital childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
11 | Maternal smoking | 1991–1994, 1996–1999, 2001
12 | Low birthweight | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001–2002
13 | Low birthweight | 1991–1994, 1996–1999, 2001
15 | Abortions | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001
17 | Breastfeeding | 1972–1974
18 | Infant mortality rates | 1996–1999, 2001–2002; (3 year data: 1996–1998, 1997–1999, 1998–2000, 2000–2002, 2001–2003, 2002–2004)
19 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001–2002; (3 year data: 1998–2000)
20 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001–2002
21 | Infant mortality rates | 1981–1989, 1991–1994, 1996–1998
24 | International mortality rates and rankings | 2001, 2002, 2003; ranking 2003, 2004
25 | International life expectancy | 1999, 2001, 2003; ranking 2002, 2003
26 | Life expectancy | 1975, 1981–1989, 1991–1994, 1996
28 | Age-adjusted death rates for selected causes | 1981–1989, 1991–1999, 2001–2002
29 | Years of potential life lost | 1991–1999, 2001; crude 1999–2003
32 | Urbanization level | 2002–2004
34 | Death rates for all causes | 1981–1989, 1991–1999, 2001–2003
35 | Diseases of heart | 1981–1989, 1991–1999, 2001–2003
36 | Cerebrovascular diseases | 1981–1989, 1991–1999, 2001–2003
37 | Malignant neoplasms | 1981–1989, 1991–1999, 2001–2003
38 | Malignant neoplasms of trachea, bronchus, and lung | 1981–1989, 1991–1999, 2001–2003
39 | Malignant neoplasm of breast | 1981–1989, 1991–1999, 2001–2003
40 | Chronic lower respiratory diseases | 1981–1989, 1991–1994, 1996–1999
41 | Human immunodeficiency virus (HIV) disease | 1988–1989, 1991–1994, 1996–1999
42 | Maternal mortality | 1981–1989, 1991–1999, 2001–2002
43 | Motor vehicle-related injuries | 1981–1989, 1991–1999, 2001–2003
44 | Homicide | 1981–1989, 1991–1999, 2001–2003
45 | Suicide | 1981–1989, 1991–1999, 2001–2003
46 | Firearm-related injuries | 1981–1989, 1991–1994, 1996–1999, 2001–2002
47 | Occupational diseases | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2002
48 | Occupational injury deaths | 1994, 1996–1999, 2002
50 | Notifiable diseases | 1985, 1988–1989, 1991–1999, 2001–2003
52 | Cancer incidence rates | 1991–1994, 1996–1999
53 | Five-year relative cancer survival rates | 1978–1980, 1984–1986
54 | Diabetes | 2001–2004,
56 | Severe headache or migraine, low back pain, and neck pain | 1998–2004
57 | Joint pain | 2003–2004
58 | Limitation of activity | 1999–2002
59 | Vision and hearing limitations | 1998–1999, 2001–2003
60 | Respondent-assessed health status | 1998–1999, 2001–2002
61 | Serious psychological distress | 1998–1999, 2000–2001, 2002–2003, 2004–2005
63 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001
64 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001
65 | Cigarette smoking | 1993–1995, 1994–1997, 2002–2004, 2003–2005
66 | Use of selected substances | 2003–2004
67 | Use of selected substances | 1981–1984, 1986–1989, 1992–1994, 1996–1999, 2001–2003
68 | Lifetime alcohol drinking status | 1998–1999, 2001–2004
69 | Heavier drinking and drinking five or more drinks in a day | 1998–1999, 2001–2004
71 | Hypertension (elevated blood pressure) | 2001–2004
72 | Serum total cholesterol levels | 2001–2004
74 | Leisure-time physical activity | 1999, 2000–2004
75 | Overweight, obesity, and healthy weight | 2001–2004
76 | Overweight among children and adolescents | 2001–2004
77 | Untreated dental caries | 1999–2000, 1999–2002
78 | No usual source of health care | 1995–1996, 1997–1998, 1999–2000, 2004–2005
79 | No usual source of health care | 2004–2005
80 | Reduced access to medical care | 1998–2004
81 | Reduced access to medical care | 2000–2001, 2004–2005
82 | No heath care visits | 1999–2000, 2003–2004, 2004–2005
83 | Health care visits | 1998–2004
85 | Vaccinations | 1996–1999, 2001
87 | Influenza vaccination | 1991, 1993–1994, 1997–1999, 2001
88 | Pneumococcal vaccination | 1991, 1993–1994, 1997–1999, 2001
89 | Mammography | 1993–1994
91 | Emergency department visits for children | 1998–2004
92 | Emergency department visits for adults | 1998–1999, 2001–2004
94 | Ambulatory care visits | 1997–1999, 2001–2002, 2004–2005
95 | Ambulatory care visits | 1997–1999, 2001–2005
96 | Dental visits | 1998–2004
98 | Prescription drug use | 1999–2000, 1999–2002
100 | Additions to mental health organizations | 1992, 1994, 1998, 2000
101 | Discharges | 1998–2004
102 | Discharges | 1991–1994, 1996–1999, 2001–2003
103 | Discharges | 1991–1999, 2001–2005
104 | Discharge rate | 1991–1999, 2001–2005
105 | Discharges | 1991–1999, 2001–2005
107 | Nursing home residents | 1997
109 | Active physicians and doctors of medicine | 2003–2005
110 | Physicians | 1970, 1980, 1987, 1989–1990, 1992–1994, 1996–1999, 2001–2002
111 | Primary care doctors of medicine | 1994, 1996–1999, 2001, 2003–2004
112 | Employees and wages | 2000–2001, 2003, 2005
113 | Health professions schools | 1996, 1998–1999, 2001–2002, 2004–2005
114 | Total enrollment of minorities in schools | 2000–2001, 2001–2002, 2002–2003, 2003–2004, 2004–2005
115 | Enrollment of women in schools | 2000–2001, 2001–2002, 2002–2003, 2003–2004, 2004–2005
117 | Mental health organizations | 1992
120 | Nursing homes | 1996–1999, 2001–2005
121 | Medicare-certified providers and suppliers | 1975, 2001, 2003, 2005
122 | Magnetic Resonance Imaging (MRI) units and Computed Tomography (CT) scanners | 2001–2002
123 | Total health expenditures as a percent of gross domestic product | 1961–1969, 1971–1979, 1981–1989, 1991–1994, 1996–1999
125 | Consumer Price Index | 2003–2004
129 | Expenditures for mental health services | 1987–1989, 1991–1994, 1996–1999, 2001
130 | Expenditures for substance abuse treatment | 1987–1989, 1991–1994, 1996–1999, 2001
131 | Expenditures for health care | 1996, 1998–1999, 2001–2004
132 | Sources of payment for health care | 1996, 1998–1999, 2001–2004
133 | Out-of-pocket health care expenses | 1998–1999, 2001
135 | Employers’ costs and health insurance | 1992–1993, 1995, 1997–1999, 2001–2003
137 | Private health insurance | 1994, 1996, 1998–1999, 2001
138 | Private health insurance | 1994, 1996, 1998–1999, 2001
139 | Medicaid coverage | 1994, 1996, 1998–1999, 2001–2002
140 | No health insurance coverage | 1994, 1996, 1998–1999, 2001–2002
141 | Health care coverage | 1993–1994, 1996–1999, 2001–2003
142 | Medicare | 2001
143 | Medicare | 1996–1998
144 | Medicare | All: 1999–2002; 1993–2003
145 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1999, 2001
146 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1999, 2001
147 | Department of Veterans Affairs | 1985, 1988–1989, 1991–1994, 1996–1999, 2001–2003
148 | Per capita personal health care expenditures | 1992–1994, 1996–1999
149 | Medicare | 1995–2005
150 | Medicaid | 1998, 2000–2001, 2003, 2004