# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the Office of Analysis and Epidemiology, National Center for Health Statistics (NCHS), under the direction of Amy B. Bernstein, Diane M. Makuc, and Linda T. Bilheimer.

Production of Health, United States, 2008, highlights, trend tables, and appendixes was managed by Amy B. Bernstein, Sheila Franco, and Virginia M. Freid. Trend tables were prepared by Amy B. Bernstein, Mary Ann Bush, Alan J. Cohen, Margaret A. Cooke, La-Tonya D. Curl, Catherine R. Duran, Sheila Franco, Virginia M. Freid, Ji-Eun Kim, Andrea P. MacKay, Livia Navon, Patricia N. Pastor, Mitchell B. Pierre, Rebecca A. Placek, Cynthia A. Reuben, and Henry Xia, with assistance from Anita L. Powell and Ilene B. Rosen. Appendix II tables and the index were assembled by Anita L. Powell. Production planning and coordination of trend tables were managed by Rebecca A. Placek. Review and clearance books were assembled by Ilene B. Rosen. Administrative and word processing assistance was provided by Lillie C. Featherstone.

Production of the Chartbook was managed by Virginia M. Freid. Data and analysis for specific charts were provided by Amy B. Bernstein, Margaret A. Cooke, Sheila Franco, Virginia M. Freid, Deborah D. Ingram, Ji-Eun Lee, Andrea P. MacKay, Livia Navon, Patricia N. Pastor, and Cynthia A. Reuben. Graphs were drafted by La-Tonya D. Curl, and data tables were prepared by Rebecca A. Placek. Technical assistance and programming were provided by Mary Ann Bush, Alan J. Cohen, Catherine R. Duran, Mitchell B. Pierre, and Henry Xia.

Publications management and editorial review were provided by Demarius V. Miller, CDC/CCHIS/NCHM/Division of Creative Services, Writer-Editor Services Branch. Oversight review for publications and electronic products was provided by Linda Torian, Acting Director, Office of Information Services. The designer was Sarah Hinkle, CDC/CCHIS/NCHM/Division of Creative Services; production was done by Jacqueline M. Davis and Zung T. Le, CDC/CCHIS/NCHM/Division of Creative Services; and printing was managed by Patricia L. Wilson, CDC/OCOO/MASO.

Electronic access through the NCHS Internet site and CD-ROM was provided by Christine J. Brown, Jacqueline M. Davis, Zung T. Le, Demarius V. Miller, Anita L. Powell, Sharon L. Ramirez, Ilene B. Rosen, and Patricia L. Wilson.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Catharine W. Burt, Marni J. Hall, Esther Hing, Lola Jean Kozak, Karen L. Lipkind, Maria F. Owings, Susan M. Schappert, and Ingrid Vassanelli; Division of Health Examination Statistics: Margaret D. Carroll, Lester R. Curtin, Bruce A. Dye, Cynthia L. Ogden, Kathy L. Radimer, Susan E. Schober, and Jaime J. Wilger; Division of Health Interview Statistics: Patricia F. Adams, Veronica E. Benson, Barbara Bloom, Robin A. Cohen, Margaret Lethbridge-Cejku, Eve Powell-Griner, Jeannine Schiller, and Charlotte A. Schoenborn; Division of Vital Statistics: Joyce C. Abma, Robert N. Anderson, Elizabeth Arias, Thomas D. Dunn, Donna L. Hoyert, Kenneth D. Kochanek, Hsiang C. Kung, Joyce A. Martin, T.J. Mathews, Arialdi M. Miniño, William D. Mosher, Sherry L. Murphy, and Stephanie J. Ventura; Office of Analysis and Epidemiology: Lara Akinbami, Li-Hui Chen, Lois Fingerhut, Tamyra C. Garcia, Deborah D. Ingram, Patricia A. Knapp, Susan Lukacs, Rashmi Tandon, and Corrine Williams; Office of the Center Director: Juan Rafael Albertorio-Diaz and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were also provided by the following organizations of the Centers for Disease Control and Prevention (CDC): Epidemiology Program Office : Samuel L. Groseclose and Patsy A. Hall; National Center for Chronic Disease Prevention and Health Promotion: Laura Kann, Steve Kinchen, Shari L. Shanklin, and Lilo Strauss (deceased); National Center for HIV, Viral Hepatitis, STD, and TB Prevention: Michael Campsmith, Rachel S. Wynn, Annemarie Wasley, and Jill Wasserman; National Center for Immunization and Respiratory Diseases: Aaron Curns; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: David Kashihara, Steven R. Machlin, and Marc W. Zodet; Centers for Medicare & Medicaid Services: Cathy A. Cowan, Frank Eppig, David A. Gibson, Deborah W. Kidd, Maggie S. Murgolo, Olivia Nuccio, and Joseph S. Regan; National Institutes of Health: Moira O’Brien, Paul W. Eggars, Marie-Joseph Horner, and Lynn A. G. Ries; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor; U.S. Department of Transportation: Lyn Cianflocco; Bureau of Justice Statistics: Allen Beck and William Sabol; Bureau of Labor Statistics: Stella Cromartie, Kay Ford, Daniel Ginsburg, Diane Herz, Sara Kline, and Stephen Pegula; Department of Veterans Affairs: William Kloiber, Dat Tran, and Henry Caplan; American Association of Colleges of Pharmacy: Jennifer M. Patton; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Osteopathic Association: Steven Andes American Dental Education Association: Richard Weaver; Association of Schools of Public Health: Mah-Sere K. Sow; and Cowles Research Group: C. McKeen Cowles.