# Highlights

Health, United States, 2007, is the 31st report on the health status of the Nation. In a chartbook and 151 trend tables, it presents current and historic information on the health of the U.S. population. The trend tables are organized around four major subject areas: health status and determinants, health care utilization, health care resources, and health care expenditures and payors. The 2007 Chartbook on Trends in the Health of Americans focuses on selected determinants and measures of health and includes a special feature on access to health care .

## Life Expectancy and Mortality

Life expectancy and infant mortality rates are often used to gauge the overall health of a population. Life expectancy shows a long-term upward trend and infant mortality shows a long-term downward trend. As overall death rates have declined, racial and ethnic disparities in mortality have persisted, but the gap in life expectancy between the black and white populations has narrowed.

In 2004, life expectancy at birth for the total population reached a record high of 77.8 years, up from 75.4 years in 1990 (Table 27).

Between 1990 and 2004, life expectancy at birth increased 3.4 years for males and 1.6 years for females. The gap in life expectancy between males and females narrowed from 7.0 years in 1990 to 5.2 years in 2004 (Table 27).

Between 1990 and 2004, life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 1990, life expectancy at birth for the white population was 7.0 years longer than for the black population. By 2004, the difference had narrowed to 5.2 years (Figure 18 and Table 27).

Overall mortality was 31% higher for black Americans than for white Americans in 2004 compared with 37% higher in 1990. In 2004, age-adjusted death rates for the black population exceeded those for the white population by 46% for stroke (cerebrovascular disease), 32% for heart disease, 23% for cancer (malignant neoplasms), and 787% for HIV disease (Table 29).

In 2004, the infant mortality rate decreased to 6.8 infant deaths per 1,000 live births (Figure 19 and Table 22).

Large disparities in infant mortality rates among racial and ethnic groups continue to exist. In 2004, infant mortality rates were highest for infants of non-Hispanic black mothers (13.6 deaths per 1,000 live births), American Indian mothers (8.4 per 1,000), and Puerto Rican mothers (7.8 per 1,000); and lowest for infants of Cuban mothers (4.6 per 1,000 live births) and Asian or Pacific Islander mothers (4.7 per 1,000) (Table 19).

The leading cause of death differs by age group. In 2004, the leading cause of death was congenital malformations for infants, unintentional injuries for people age 1–44 years, cancer for middle-age adults age 45–64 years, and heart disease for adults age 65 years and over (Table 32).

Age-adjusted mortality from heart disease, the leading cause of death overall, declined 33% between 1990 and 2004, continuing a long-term downward trend (Figure 20 and Table 36).

Age-adjusted mortality from cancer (malignant neoplasms), the second leading cause of death overall, decreased 14% between 1990 and 2004 (Figure 20 and Table 38).

The age-adjusted death rate for motor vehicle-related injuries has remained stable since the early 1990s following a period of decline. Death rates for motor vehicle-related injuries are higher at age 15–24 years and 75 years and over than at other ages (Table 44).

The age-adjusted death rate for HIV disease has declined slowly since 1998, after a sharp decrease between 1995 and 1998. The death rate for HIV disease is higher at age 35–54 years than at other ages (Table 42).

The homicide rate for black males 15–24 years of age decreased sharply from the early to the late 1990s and has remained relatively stable since then (Table 45). Homicide continues to be the leading cause of death for young black males 15–24 years of age.

In 2004, young American Indian males 15–24 years of age continued to have substantially higher death rates for motor vehicle-related injuries and for suicide than young males in other race or ethnicity groups. Death rates for the American Indian population are known to be underestimated (Tables 44 and 46).

The suicide rate for non-Hispanic white men 65 years of age and over is higher than in other groups. In 2004, the suicide rate for older non-Hispanic white men was about two to three times the rate for older men in other race or ethnicity groups and nearly 8 times the rate for older non-Hispanic white women (Table 46).

## Health Behaviors and Risk Factors

Health behaviors have a significant effect on health status. Pregnant teenagers are less likely to receive early prenatal care and more likely to drop out of school and to live in poverty, than are other parents. Heavy and chronic use of alcohol and use of illicit drugs increase the risk of disease and injuries. Cigarette smoking increases the risk of lung cancer, heart disease, emphysema, and other diseases. Obesity increases the risk of heart disease, diabetes, and stroke. Regular physical activity reduces the risk of disease and enhances mental and physical functioning.

The birth rate for teenagers declined in 2005 (preliminary data) for the 14th consecutive year, to 40.4 births per 1,000 women age 15–19 years, 2% lower than in 2004. Rates declined 3% for teenagers age 15–17 years and remained unchanged for teenagers age 10–14 years and 18–19 years (Table 4).

In 2005 (preliminary data), the birth rate for unmarried women reached a record high of 47.6 births per 1,000 unmarried women age 15–44 years, up 3% from 2004. In 2005, 37% of all births were to unmarried women and the percentages generally increased for all age, race, and Hispanic origin subgroups (Table 10).

Low birthweight is associated with elevated risk of death and disability in infants. In 2005 (preliminary data), the low birthweight rate (less than 2,500 grams, or 5.5 pounds, at birth) increased to 8.2%, up from 7.0% in 1990 (Table 13).

Between 1988–1994 and 2003–2004, the prevalence of overweight among preschool-age children 2–5 years of age almost doubled, from about 7% to 14% (Figure 13 and Table 69).

The prevalence of overweight among school-age children increased more than 60% between 1988–1994 and 2003–2004. Among children 6–11 years of age, overweight increased from 11% to 19%. The prevalence of overweight among adolescents 12–19 years of age grew from 11% to 17% (Figure 13 and Tables 69 and 75).

Between 1993 and 2005, the percentage of high school students who reported attempting suicide (8%–9%) and whose suicide attempts required medical attention (2%–3%) remained fairly constant. Girls were more likely than boys to consider or attempt suicide. However, in 2004, adolescent boys (15–19 years of age) were almost 4 times as likely to die from suicide as were adolescent girls, in part reflecting their choice of more lethal methods, such as firearms (Tables 46 and 62).

In 2005, among current drinkers 18 years of age and over, about one-third reported consuming five or more alcoholic drinks in one day during the past year, with the highest proportion among young adults 18–24 years of age (55%). In 2005, among current drinkers 18–24 years of age, 67% of men and 41% of women reported consuming five or more alcoholic drinks on at least one day in the past year (Table 68).

Between 2003 and 2005, the percentage of high school students who reported smoking cigarettes in the past month remained stable at 22%–23% after declining from 36% in 1997 (Figure 9).

In 2005, 21% of U.S. adults were current cigarette smokers, the same percentage as in 2004, suggesting that the decline in cigarette smoking prevalence might be stalling (Figure 9 and Table 63).

Children with low family income are more likely to have high blood cotinine levels (a marker for exposure to secondhand smoke) than children living in higher income families. In 2001–2004, children living in families with income below 200% of the poverty level were at least twice as likely to have had a high blood cotinine level as children living in higher income families (22%–28% compared with 10%) (Figure 10).

Among adults 20–74 years of age, overweight and obesity rates have increased since 1960–1962. These increases were driven largely by increases in the percentage of adults who were obese. From 1960–1962 through 2003–2004, the percentage of adults who were overweight but not obese remained steady at 32%–34% (age-adjusted). During that time period, the percentage of adults who were obese increased from 13% to 34% (age-adjusted) (Figure 13 and Table 74).

In 1999–2004, weekly restaurant meal consumption varied by age. Eating four or more weekly restaurant meals ranged from 9% among children 1–12 years to 32% among adults 18–44 years of age. Adults 65 years and over had the lowest likelihood of eating at least one weekly restaurant meal (Figure 12).

In 2005, almost one-third of adults 18 years of age and over engaged in regular leisure-time physical activity. Adults in families with income above twice the poverty level were more likely to engage in regular leisure-time physical activity (34%) than adults in lower income families (20%–22%) (age-adjusted) (Table 73).

## Health Status and Health Conditions

Measures of health status include respondent-assessed health status, limitation in activity caused by chronic conditions, and serious psychological distress. Measures of morbidity presented in this report include the incidence and prevalence of selected specific diseases and conditions.

In 2005, the percentage of noninstitutionalized adults reporting their health as fair or poor ranged from 6% of those age 18–44 years to 30% of those age 75 years and over. The proportion of adults with fair or poor health was higher among non-Hispanic black and Hispanic persons compared with non-Hispanic white persons (Table 60).

In 2005, activity limitation caused by chronic health conditions was reported for 7% of children under the age of 18 years. Among school-age children (5–17 years of age), learning disabilities and Attention Deficit/Hyperactivity Disorder (ADHD or ADD) were frequently reported as a cause of activity limitation (Figure 14 and Table 58).

Arthritis and other musculoskeletal conditions were the leading causes of activity limitation among working-age adults 18–64 years of age in 2004–2005. Mental illness was the second most frequently mentioned condition causing activity limitation among adults 18–44 years of age and the third most frequently mentioned among adults 45–54 years of age (Figure 15).

In 2004–2005, 3% of the noninstitutionalized population reported having serious psychological distress. Adults living below the poverty level were more than five times as likely to report serious psychological distress as adults in families with income of at least twice the poverty level (8.6% compared with 1.7%) (Table 61).

The prevalence of hypertension, defined as elevated blood pressure or taking antihypertensive medication, increases with age. In 2001–2004, 36% of men and 35% of women age 45–54 years had hypertension, compared with 67% of men and 82% of women age 75 years and over (Table 70).

Between 1988–1994 and 2001–2004, the percentage of both men and women 55 years and over with high total serum cholesterol levels (greater than 240 mg/dL) declined substantially. However, older women were more likely to have high serum cholesterol than older men. In 2001–2004, 26% of women age 65–74 years had high serum cholesterol, compared with 11% of men age 65–74 years (Table 71).

In 2001–2004, the prevalence of diabetes (including both diagnosed and undiagnosed) increased with age from 11% among adults 40–59 years of age to 23% among adults 60 years of age and over. The percentage of adults with undiagnosed diabetes was 3% among those 40–59 years of age and 6% among those 60 years of age and over (Table 55).

Between 1988–1994 and 2001–2004, approximately one-quarter of adults 20–64 years of age had untreated dental caries, down from nearly one-half in 1971–1974 (Table 76).

In 2005, 28% of adults 18 years of age and over had any low back pain in the past 3 months and 15% reported having a severe headache or migraine in the past 3 months (age-adjusted) (Table 56).

In 2005, approximately 2.2 million workplace injuries and illnesses in the private sector involved days away from work, job transfer, or restricted duties at work for a rate of 2.4 cases per 100 full-time workers (FTW). The transportation and warehousing industry reported the highest injury and illness rate, with 4.6 cases per 100 FTW. The next highest rates were reported by the manufacturing industry (3.5 per 100 FTW) and the construction industry (3.4 per 100 FTW) (Table 50).

## Health Care Expenditures and Payors

The United States spends more on health per capita than any other country, and U.S. health spending continues to increase, though the rate of increase has slowed for the third consecutive year. Spending increases are due to increased intensity and cost of services and a higher volume of services needed to treat an aging population. Major payors for health care include private health insurers and public programs such as Medicare and Medicaid. Medicaid is jointly funded by the federal and state governments to provide health care for certain groups of low-income persons. Medicare is funded by the federal government and covers the health care of most persons 65 years of age and over and disabled persons.

The United States spends a larger share of its gross domestic product (GDP) on health than does any other major industrialized country. In 2004, the United States devoted 15% of its GDP to health compared with 12% in Switzerland and more than 10% in France, Germany, Iceland, and Portugal, the countries with the next highest shares (Table 120).

In 2005, national health care expenditures in the United States totaled $2 trillion, a 6.9% increase from 2004. The rate of increase slowed for the third consecutive year, though it was still higher than the growth in the gross domestic product (GDP) (Tables 121).

Prescription drug expenditures increased almost 6% in 2005, a much slower rate than in previous years. The price of prescription drugs and medical supplies increased 4% in the Consumer Price Index in 2005 and 2006 (Tables 122 and 124).

Expenditures for hospital care accounted for 31% of all national health expenditures in 2005. Physician and clinical services accounted for 21% of the total in 2005, prescription drugs for 10%, and nursing home care for 6% (Table 124).

In 2005, 34% of personal health care expenditures were paid by the federal government and 11% by state and local government; private health insurance paid 36% and consumers paid 15% out-of-pocket (Figure 6 and Table 125).

In 2003, Medicaid (26%) and private health insurance (24%) funded the largest shares of mental health services expenditures (Figure 7). In contrast, other state and local government expenditures (excluding Medicaid) funded the largest share (40%) of substance abuse treatment expenditures (Figures 7 and 8).

In 2003, national health expenditures for mental health services were about $100 billion. Almost one-quarter of these expenditures were for retail prescription drugs ($23 billion) (Table 126).

National health expenditures for substance abuse treatment increased by about 50% from 1986 to 2003 (inflation-adjusted). In 2003, national health expenditures for substance abuse treatment exceeded $20 billion (unadjusted dollars) (Table 127).

In 2004, 97% of persons 65 years of age and over in the civilian noninstitutionalized population had medical expenses that averaged about $8,900 per person with expenses. Almost one-fifth of expenses was paid out-of-pocket, 16% by private insurance, and 64% by public programs (primarily Medicare) (Tables 128 and 129).

In 2006, the Medicare program had about 43 million enrollees and expenditures of $408 billion, up from $336 billion the previous year. Expenditures for the first year of the new Medicare drug program (Part D), introduced in 2006, were $47 billion (Table 141).

Of the 33 million Medicare enrollees in the fee-for-service program in 2004, 12% were 85 years of age and over and 16% were under 65 years of age (Table 142).

In 2004, children under 21 years of age accounted for 48% of Medicaid recipients but only 17% of expenditures. Aged, blind, and disabled persons accounted for 22% of recipients and 66% of expenditures (Table 144).

## Health Care System Influences, Personnel, and Resources

Major changes continue to occur in the delivery of health care in the United States, driven in part by changes in payment policies intended to rein in rising costs and by advances in technology that have allowed more complex treatments to be performed on an outpatient basis. Hospital inpatient utilization has been stable in recent years. The ratio of physicians per population continues to increase slowly, but supply is not equally distributed across the country. The supply of other practitioners, including pharmacists and nurses, may not be increasing as rapidly as needed to keep pace with our aging population.

In 2005, 41% of doctor visits were to specialty care physicians, up from 34% in 1980. During this period, the proportion of office-based doctor visits to general and family practice physicians decreased from 34% to 22% (Table 93).

Physician supply varied greatly by geographic area in 2004 with only 11% of counties having a patient care physician to population ratio above the overall national ratio of 24 physicians per 10,000 population. Similarly, 14% of counties had a ratio of obstetricians or gynecologists greater than the national ratio of 3 obstetricians or gynecologists per 10,000 females 15 years of age and over. In 2004, almost 50% of counties had no practicing obstetricians or gynecologists (Figures 22 and 23).

Between 1999 and 2005, the number of dental hygienists and assistants, massage therapists, diagnostic medical sonographers, medical equipment preparers, medical assistants, and pharmacy technicians increased by 5%–10% annually. During this period, the hourly wages of radiation therapists, nuclear medicine technologists, massage therapists, pharmacists, and physician assistants rose the most, at 6%–7% annually (Table 109).

In 2004, the United States had among the highest number of Magnetic Resonance Imaging (MRI) units and Computed Tomography (CT) scanners per population among OECD countries reporting 2004 data. The U.S. had 27 MRI units and 32 CT scanners per one million population. Other countries with high numbers of MRI units included Austria (15 MRI units per one million population), Iceland (17), and Switzerland (14). Countries with high numbers of CT scanners included Austria (29 CT scanners per one million population), Italy (21), and South Korea (32) (Table 119).

In 2005, 63% of surgeries were performed on an outpatient basis compared with 51% in 1990 and 16% in 1980 (Table 103).

Between 1990 and 2005, the number of community hospital beds declined 13%, from about 927,000 to 802,000. Since 1990, the community hospital occupancy rate has remained steady at 62%–67% (Table 113).

Between 1990 and 2004, the overall rate of inpatient mental health beds per 100,000 civilian population in the United States declined by 45%. In state and county mental hospitals, the number of mental health beds per population declined by 53%, in private psychiatric hospitals the decline was 48%, and in nonfederal general hospital psychiatric services the decline was 34% (Table 114).

In 2006, there were about 1.7 million nursing home beds in about 16,000 nursing homes certified for use by Medicare and Medicaid beneficiaries. Between 1995 and 2006, nursing home bed occupancy was relatively stable, estimated at 84% in 2006. Occupancy rates were 90% or higher in 14 states and the District of Columbia in 2006 (Table 117).

## Special Feature: Access to Health Care

Identifying which Americans do not receive potentially beneficial health care services, and the reasons underlying suboptimal use of services, is essential to identifying solutions that can improve access to needed health care.

### Foregone or delayed health care due to cost

The percentage of Americans who reported not receiving needed health care services (as determined by the respondents) varies by age, family income, insurance coverage, and state of residence.

In 2005, 19% of adults 18 years of age and over—more than 40 million people—reported that they needed and did not receive one or more of the following services in the past year because they could not afford them: medical care, prescription medicines, mental health care, dental care, or eyeglasses (Figure 21).

In 2005, about 12% of adults 18 years of age and over reported that they did not receive needed dental care; 7% did not purchase needed eyeglasses, and about 9% did not purchase needed prescription drugs due to cost (Figure 21).

Adults 18–64 years of age were more likely than older adults or children to report not receiving needed medical care or delaying their medical care due to cost. In 2005, 7% of adults 18–64 years of age reported that they did not get needed medical care during the past 12 months, 9%–10% delayed medical care, and 9%–10% did not get needed prescription drugs due to the cost. Compared with 1997, in 2005, more adults 18–64 years of age reported not getting needed medical care and needed prescription drugs due to cost (Table 79).

Almost all adults 65 years of age and over have Medicare coverage. Despite this health insurance coverage, in 2005, 4%–6% of those with income below or near the poverty level did not get needed medical care during the past 12 months, 6%–9% delayed their medical care, and 9%–12% did not get the prescription drugs they needed due to the cost. Medicare coverage for prescription drugs began in 2006 (Table 79).

In 2004–2005, reduced access to medical care due to cost varied across the 25 most populous states. The percentage of residents who reported not getting needed care due to cost ranged from 3%–9%. The range of those reporting delaying medical care due to cost was 5%–11%. The percentage reporting not getting needed prescription drugs due to cost varied among the 25 states from 4%–14% (Table 80).

In 2005, 19% of people under age 65 years of age who were uninsured for all or part of the preceding year did not receive needed medical care in the past 12 months due to cost, compared with 2% of people covered by health insurance for the full year (Table 79 and Figure 33).

In 2004, 27% of people with family income below the poverty line paid more than 10% of their after-tax family income on out-of-pocket health care expenditures (including health insurance premiums) (Figure 31).

The burden of out-of-pocket expenses for health care varies considerably by age. In 2004, more than one-half of people 75 years of age and over with health care expenses paid $1,000 or more out-of-pocket, compared with 28% of those 45–64 years of age, and 13% of adults 18–44 years of age (Table 130).

### Barriers to health care use

Often-cited barriers to accessing needed health care include a lack of transportation and not having a usual source of medical care. Supply shortages or maldistribution of services can also create obstacles to the timely receipt of health care services.

In 2004–2005, about 5%–6% of adults 45–64 years of age with hypertension, a serious heart condition, or diabetes did not report a usual source of care (Figure 26).

In 2004–2005, 6% of adults living below the poverty level reported delaying health care in the past 12 months due to a lack of transportation compared with less than 1% of adults living at 200% or more of the poverty level. On average, women were more likely to report delaying care due to a lack of transportation than men (data table for Figure 27).

From 1988 to 2004 the percentage of patients receiving kidney transplants within two years of being added to the waiting list declined 56% for white patients and about 65% for black patients, in large part because the increase in the number of patients on the waiting list has not been met by a concurrent increase in the number of donated kidneys (Figure 25).

### Lack of health insurance

Access to health care is often equated with lack of health insurance coverage, which has been established as a major barrier to receiving most health care services.

In 2005, the percentage of the population under 65 years of age with no health insurance coverage (public or private) at a point in time was 16.4%. Between 1995 and 2005, this percentage fluctuated between 16.1% and 17.5% (Figure 28 and Table 139).

Among the under 65 years of age population, the poor and near poor (those with family income less than 200% of poverty) were much more likely to be uninsured at a point in time than persons in higher income families (Table 139).

In 2005, 9% of children under 18 years of age were uninsured at a point in time. Between 2000 and 2005, among children in families with income just above the poverty level (100%–150% of poverty), the percentage uninsured dropped from 25% to 15% (Table 139), while the percentage with Medicaid or State Children's Health Insurance Program (SCHIP) coverage increased from 35% to 49% (Table 138).

In 2005, 29% of young adults 18–24 years of age were uninsured at a point in time. This age group was more than twice as likely to be uninsured as those 45–64 years of age (Table 139).

In 2005, among persons under 65 years of age, those of Hispanic origin and American Indians and Alaska Natives were more likely to be uninsured at a point in time than were those in other racial and ethnic groups (Table 139).

Many people under 65 years of age, particularly those with a low family income, do not have health insurance coverage consistently throughout the year. In 2005, one-fifth of people under 65 years of age were uninsured for at least part of the 12 months prior to interview. Two-fifths of people of Mexican origin were uninsured for at least part of the 12 months prior to interview (Figure 29).

The likelihood of being uninsured varied among the states. In 2003–2005, the average percentage of the population with no health insurance coverage ranged from less than 10% in Minnesota, Hawaii, and Iowa, to 25% in Texas (Table 151).

About one-half of the uninsured population were non-Hispanic white persons with the other half being people of other races and ethnicities (Figure 30).

### Differential utilization of services by population group

Access is often studied by examining whether rates of service use are at recommended or expected levels, or whether population groups differ in use of services. Lower rates of service use among a population group may reflect an access barrier in the lower-use group.

The percentage of mothers receiving prenatal care in the first trimester of pregnancy remained unchanged from 2003 to 2004 at 84% for the 43 reporting areas for which comparable trend data were available. In 2004, the percentage of mothers with early prenatal care varied substantially by race and ethnicity, from 70% for American Indian or Alaska Native mothers to 89% for non-Hispanic white mothers (Table 7).

In 2006, 77% of children 19–35 months of age received the combined vaccination series of four doses of DTaP (diphtheria-tetanus-acellular pertussis) vaccine, three doses of polio vaccine, one dose of MMR (measles-mumps-rubella vaccine), three doses of Hib (Haemophilus influenzae type b) vaccine, three doses of hepatitis B vaccine, and one dose of varicella vaccine. Children living below the poverty threshold were less likely than were children living at or above poverty to have received the combined vaccination series (74% compared with 78%) (Table 83).

Between 1987 and 1999, mammography usage in the past 2 years among women 40 years of age and over rose from 29% to 70% and has been between 67%–70% through 2005. Mammography levels are lower among Hispanic and Asian women compared with non-Hispanic black and white women (Table 87).

In 2004–2005, 6% of children under 6 years of age and 14% of children 6–17 years of age had no health care visit to a doctor or clinic within the past 12 months. Uninsured children under age 18 were almost three times as likely as those with insurance to have no recent health care visits (Table 81).

In 2005, about one-fourth of children 2–17 years of age did not have a dental visit in the past year. Children with family income below 200% of poverty were more likely to lack a recent dental visit than those with higher family income (Table 94).

In 2005, about one-half of adults with family income below 200% of the poverty level did not have a dental visit in the past year (Figure 34).

In 1999–2002, nearly 13% of non-Hispanic white women reported antidepressant drug use in the past month, more than twice the percentage of non-Hispanic black women and women of Mexican origin (age-adjusted; Figure 36).

In 2000–2005, about 44% of adults 50 years of age and over reported ever having had a procedure for detecting colorectal cancer using colonoscopy, proctoscopy, or sigmoidoscopy. Among insured adults 50–64 years of age, the proportion who ever had a scope procedure was lower among Hispanic and non-Hispanic black adults than non-Hispanic white adults (Figure 35).

In 1973–1974, the nursing home resident rate for the white population 65 years of age and over was more than twice that for the black population (61.2 compared with 28.2 per 1,000 population; age-adjusted). By 2004, the resident rate for the black population (49.9) exceeded that for the white population (34.0) (Table 104).