# Appendix III

## Additional Data Years Available

For trend tables spanning long periods, only selected data years are shown to highlight major trends. Additional years of data are available for some of the tables in electronic spreadsheets available through the Internet and on CD-ROM.

To access spreadsheet files on the Internet, go to the Health, United States website at www.cdc.gov/nchs/hus.htm, scroll down to "Spreadsheet Files," and click on 2007 Edition.

Downloadable spreadsheet files for trend tables, many of which include more data years than are shown in the printed report, are available in Excel. Standard errors are included in spreadsheet files for trend tables based on the National Health Interview Survey (NHIS), National Health and Nutrition Examination Survey (NHANES), and National Survey of Family Growth (NSFG).

Spreadsheet files in Excel are also available on a CD-ROM. A limited supply of CD-ROMs are available from the National Center for Health Statistics upon request, while supplies last, or CD-ROMs may be purchased from the Government Printing Office.

Table number | Table topic | Additional data years available
1 | Resident population | 2001–2002
2 | Inmates in state or federal prisons and local jails | 2001–2002
3 | Poverty | 1986–1989, 1991–1994, 1996–1999, 2001–2002
4 | Fertility rates and birth rates | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
5 | Live births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2002
6 | Twin births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996, 1998–1999, 2001
7 | Prenatal care | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
9 | Teenage childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999
10 | Nonmarital childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999
11 | Maternal education | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
12 | Maternal smoking | 1991–1994, 1996–1999, 2001
13 | Low birthweight | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001
14 | Low birthweight | 1991–1994, 1996–1999, 2001
16 | Abortions | 1981–1984, 1986–1989, 1991–1994, 1996–1998
18 | Breastfeeding | 1972–1974
19 | Infant mortality rates | 1996–1999, 2001, 1996–1998, 1997–1999, 1998–2000, 2000–2002, 2001–2003
20 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001
21 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001
22 | Infant mortality rates | 1981–1989, 1991–1994, 1996–1997
25 | International mortality rates and rankings | 2001, ranking 2003
26 | International life expectancy | 1999, 2001, ranking 2002
27 | Life expectancy | 1975, 1981–1989, 1991–1994
29 | Age-adjusted death rates for selected causes | 1981–1989, 1991–1999, 2001
30 | Years of potential life lost | 1991–1999 2001, crude 1999–2003
35 | Death rates for all causes | 1981–1989, 1991–1999, 2001–2002
36 | Diseases of heart | 1981–1989, 1991–1999, 2001–2002
37 | Cerebrovascular diseases | 1981–1989, 1991–1999, 2001–2002
38 | Malignant neoplasms | 1981–1989, 1991–1999, 2001–2002
39 | Malignant neoplasms of trachea, bronchus, and lung | 1981–1989, 1991–1999, 2001–2002
40 | Malignant neoplasm of breast | 1981–1989, 1991–1999, 2001–2002
41 | Chronic lower respiratory diseases | 1981–1989, 1991–1994, 1996–1999, 2001
42 | Human immunodeficiency virus (HIV) disease | 1988–1989, 1991–1994, 1996–1999, 2001
43 | Maternal mortality | 1981–1989, 1991–1999, 2001
44 | Motor vehicle-related injuries | 1981–1989, 1991–1999, 2001–2002
45 | Homicide | 1981–1989, 1991–1999, 2001–2002
46 | Suicide | 1981–1989, 1991–1999, 2001–2002
47 | Firearm-related injuries | 1981–1989, 1991–1994, 1996–1999, 2001
48 | Occupational diseases | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
49 | Occupational injury deaths | 1993–1994, 1996–1998
51 | Notifiable diseases | 1985, 1988–1989, 1991–1999, 2001–2002
53 | Cancer incidence rates | 1991–1994, 1996–1998
54 | Five-year relative cancer survival rates | 1978–1980, 1984–1986
55 | Diabetes | 1999–2002
56 | Severe headache or migraine, low back pain, and neck pain | 1998–2003
57 | Joint pain | 2003
58 | Limitation of activity | 1999–2002
59 | Vision and hearing limitations | 1998–1999, 2001–2002
60 | Respondent-assessed health status | 1998–1999, 2001
61 | Serious psychological distress | 1998–1999, 1999–2000, 2001–2002, 2003–2004
63 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999
64 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999
65 | Cigarette smoking | 1993–1995, 1994–1997, 2002–2004
66 | Use of selected substances | 2003
67 | Use of selected substances | 1981–1989, 1992–1994, 1996–1999, 2001–2002
68 | Alcohol consumption | 1998–2002
70 | Hypertension (elevated blood pressure) | 1999–2002
71 | Serum cholesterol levels | 1999–2002
73 | Leisure-time physical activity | 1999, 2000–2003
74 | Overweight, obesity, and healthy weight | 1999–2002
75 | Overweight among children and adolescents | 1999–2002
76 | Untreated dental caries | 1999–2000, 1999–2002
77 | No usual source of health care | 1995–1996, 1997–1998, 1999–2000
79 | Reduced access to medical care | 1998–2003
81 | No heath care visits | 1999–2000, 2003–2004
82 | Health care visits | 1998–2003
83 | Vaccinations | 1996–1999
84 | Vaccination coverage among children | 1996–1997
85 | Influenza vaccination | 1991, 1993–1994, 1997–1999
86 | Pneumococcal vaccination | 1991, 1993–1994, 1997–1999
87 | Mammography | 1993–1994
89 | Emergency department visits for children | 1998–2003
90 | Emergency department visits for adults | 1998–1999, 2001–2003
91 | Injury-related visits | 1997–1998, 1998–1999, 2000–2001, 2001–2002, 2002–2003, 2003–2004
92 | Ambulatory care visits | 1997–1999, 2001–2002, 2004
93 | Ambulatory care visits | 1997–1999, 2001–2004
94 | Dental visits | 1998–2003
96 | Prescription drug use | 1999–2000
97 | Additions to mental health organizations | 1992, 1994, 1998, 2000
98 | Discharges | 1998–2003
99 | Discharges | 1991–1994, 1996–1999, 2001
100 | Rates of discharges | 1995–1999, 2001–2004
101 | Discharges | 1995–1999, 2001–2004
102 | Inpatient procedures | 1991–1992, 1992–1993, 1993–1994, 2001–2002, 2002–2003, 2003–2004
104 | Nursing home residents | 1997
106 | Active physicians and doctors of medicine | 2002–2003
107 | Physicians | 1970, 1980, 1987, 1989–1990, 1992–1994, 1996–1999, 2001
108 | Primary care doctors of medicine | 1994, 1996–1999, 2001, 2003
109 | Employees and wages | 2001–2003
110 | Health professions schools | 1996, 1998–1999, 2001–2004
111 | Total enrollment of minorities in schools | 2000–2001, 2001–2002, 2002–2003, 2003–2004
112 | Enrollment of women in schools | 2000–2001, 2001–2002, 2002–2003, 2004–2005
114 | Mental health organizations | 1992
117 | Nursing homes | 1996–1999, 2001–2004
118 | Medicare-certified providers and suppliers | 1975, 1996, 1998, 2001, 2003
126 | Expenditures for mental health services | 1987–1989, 1991–1994, 1996–1999, 2001
127 | Expenditures for substance abuse treatment | 1987–1989, 1991–1994, 1996–1999, 2001
128 | Expenditures for health care | 1996, 1998–1999, 2001–2003
129 | Sources of payment for health care | 1996, 1998–1999, 2001–2003
130 | Out-of-pocket health care expenses | 1998–1999
132 | Employers' costs and health insurance | 1992–1993, 1995, 1997, 1999, 2001
134 | Nursing home average monthly charges | 1997, 1999
135 | Mental health expenditures | 1992
136 | Private health insurance | 1994, 1996, 1998–1999
137 | Private health insurance | 1994, 1996, 1998–1999
138 | Medicaid coverage | 1994, 1996, 1998–1999, 2001
139 | No health insurance coverage | 1994, 1996, 1998–1999, 2001
140 | Health care coverage | 1993–1994, 1996–1999, 2001–2003
142 | Medicare | 1996
143 | Medicare | All: 1999–2002, 1993–2002
144 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1999
145 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1999
146 | Department of Veterans Affairs | 1985, 1988–1989, 1991–1994, 1996–1999, 2001
147 | State mental health agency per capita expenditures | 1983, 1987, 2002
148 | Medicare | 1995–2003
149 | Medicaid | 1998, 2000–2001, 2003
150 | Health maintenance organizations | 1994, 1996–1997, 1999, 2001–2004