# Appendix III - Additional Data Years Available

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06tables/)

For trend tables spanning long periods, only selected data years are shown to highlight major trends. Additional years of data are available for some of the tables in electronic spreadsheets available through the Internet and on CD-ROM.

To access spreadsheet files on the Internet, go to the Health, United States website at www.cdc.gov/nchs/hus.htm, scroll down to "Spreadsheet Files," and click on 2006 Edition.

Downloadable spreadsheet files for trend tables, many of which include more data years than are shown in the printed report, are available in Excel. Standard errors are included in spreadsheet files for trend tables based on the National Health Interview Survey (NHIS), National Health and Nutrition Examination Survey (NHANES), and National Survey of Family Growth (NSFG).

Spreadsheet files in Excel are also available on CD-ROM. A limited supply of CD-ROMs is available from the National Center for Health Statistics upon request, or CD-ROMs may be purchased from the Government Printing Office.

Table number | Table topic | Additional data years available
1 | Resident population | 2001
3 | Poverty | 1986–1989, 1991–1994, 1996–1999, 2001
4 | Fertility rates and birth rates | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
5 | Live births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2002
6 | Twin births | 1972–1974, 1976–1979, 1981–1984, 1986–1989, 1991–1994, 1996, 1998–1999, 2001
7 | Prenatal care | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
9 | Teenage childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999
10 | Nonmarital childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999
11 | Maternal education | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001
12 | Maternal smoking | 1991–1994, 1996–1999, 2001
13 | Low birthweight | 1981–1984, 1986–1989, 1991–1994, 1996–1998, 2001
14 | Low birthweight | 1991–1994, 1996–1999, 2001
16 | Abortions | 1981–1984, 1986–1989, 1991–1994, 1996–1997
18 | Breastfeeding | 1972–1974
19 | Infant mortality rates | 1996–1998, 2001
20 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1998
21 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999
22 | Infant mortality rates | 1981–1989, 1991–1994, 1996
26 | International life expectancy | 1999
27 | Life expectancy | 1975, 1981–1989, 1991–1994
29 | Age-adjusted death rates for selected causes | 1981–1989, 1991–1999
30 | Years of potential life lost | 1991–1999; Crude 1999–2002
35 | Death rates for all causes | 1981–1989, 1991–1999, 2001
36 | Diseases of heart | 1981–1989, 1991–1999, 2001
37 | Cerebrovascular diseases | 1981–1989, 1991–1999, 2001
38 | Malignant neoplasms | 1981–1989, 1991–1999, 2001
39 | Malignant neoplasms of trachea, bronchus, and lung | 1981–1989, 1991–1999, 2001
40 | Malignant neoplasm of breast | 1981–1989, 1991–1999, 2001
41 | Chronic lower respiratory diseases | 1981–1989, 1991–1994, 1996–1999
42 | Human immunodeficiency virus (HIV) disease | 1988–1989, 1991–1994, 1996–1999
43 | Maternal mortality | 1981–1989, 1991–1999
44 | Motor vehicle-related injuries | 1981–1989, 1991–1999, 2001
45 | Homicide | 1981–1989, 1991–1999, 2001
46 | Suicide | 1981–1989, 1991–1999, 2001
47 | Firearm-related injuries | 1981–1989, 1991–1994, 1996–1999
48 | Occupational diseases | 1981–1984, 1986–1989, 1991–1994, 1996–1999
49 | Occupational injury deaths | 1993–1994, 1996–1997
51 | Notifiable diseases | 1985, 1988–1989, 1991–1999, 2001
53 | Cancer incidence rates | 1991–1994
54 | Five-year relative cancer survival rates | 1978–1980, 1984–1986
55 | Diabetes | 1999–2002
56 | Severe headache or migraine, low back pain, and neck pain | 1998–2002
58 | Limitation of activity | 1999–2001
59 | Vision and hearing limitations | 1998–1999, 2001
60 | Respondent-assessed health status | 1998–1999
63 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1998
64 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1998
65 | Cigarette smoking | 1993–1995, 1994–1997
67 | Use of selected substances | 1981–1989, 1992–1994, 1996–1999, 2001
68 | Alcohol consumption | 1998–2002
69 | Hypertension (elevated blood pressure) | 1999–2002
70 | Serum cholesterol levels | 1999–2002
71 | Mean energy and macronutrient intake | 1999–2000
72 | Leisure-time physical activity | 1999, 2000–2002
73 | Overweight, obesity, and healthy weight | 1999–2002
74 | Overweight among children and adolescents | 1999–2002
75 | Untreated dental caries | 1999–2000
76 | No usual source of health care | 1995–1996, 1997–1998, 1999–2000
78 | Reduced access to medical care | 1998–2002
79 | No heath care visits | 1999–2000
80 | Health care visits | 1998–2002
81 | Vaccinations | 1996–1998
82 | Vaccination coverage among children | 1996
83 | Influenza and pneumococcal vaccination | 1991, 1993–1994, 1997–1998
84 | Mammography | 1993
86 | Emergency department visits for children | 1998–2002
87 | Emergency department visits for adults | 1998–1999, 2001–2002
88 | Injury-related visits | 1997–1998, 1998–1999, 2000–2001, 2001–2002, 2002–2003
89 | Ambulatory care visits | 1997–2001
90 | Ambulatory care visits | 1997–1999, 2001–2003
91 | Dental visits | 1998–2002
93 | Prescription drug use | 1999–2000
94 | Additions to mental health organizations | 1992, 1998
95 | Discharges | 1998–2001
96 | Discharges | 1991–1994, 1996–1999
97 | Rates of discharges | 1995–1999, 2001–2003
98 | Discharges | 1995–1999, 2001–2003
99 | Inpatient procedures | 1991–1992, 1992–1993, 2001–2002, 2002–2003
100 | Hospital admissions | 1985, 1991–1994, 1996–1999, 2001
101 | Nursing home residents | 1997
102 | Nursing home residents | 1997
104 | Active physicians and doctors of medicine | 2002–2003
105 | Physicians | 1970, 1980, 1987, 1989–1990, 1992–1994, 1996–1999
106 | Primary care doctors of medicine | 1994, 1996–1999, 2001
108 | Employees and wages | 2001, 2003
109 | Health professions schools | 1996, 1998–1999, 2001–2002
110 | Total enrollment of minorities in schools | 2000–2001, 2001–2002, 2002–2003
111 | Enrollment of women in schools | 2000–2001, 2001–2002, 2002–2003
112 | Hospitals | 1985, 1991–1994, 1996–1999, 2001–2002
113 | Mental health organizations | 1992
114 | Community hospital beds | 1985, 1988–1989, 1995–1999, 2001–2003
115 | Occupancy rates | 1985, 1988–1989, 1995–1999, 2001–2003
116 | Nursing homes | 1996, 1998–1999, 2001–2003
118 | Medicare-certified providers and suppliers | 1975, 1998, 2001
125 | Expenditures for health care | 1996, 1998–1999, 2001–2002
126 | Sources of payment for health care | 1996, 1998–1999, 2001–2002
127 | Out-of-pocket health care expenses | 1998
129 | Employers' costs and health insurance | 1992–1993, 1995, 1997, 1999, 2001
130 | Hospital expenses | 1975, 1985, 1991–1994, 1996–1998, 2001–2002
131 | Nursing home average monthly charges | 1997
132 | Mental health expenditures | 1992
133 | Private health insurance | 1994, 1996, 1998
134 | Medicaid coverage | 1994, 1996, 1998, 2001
135 | No health insurance coverage | 1994, 1996, 1998, 2001
136 | Health care coverage | 1993–1994, 1996–1999, 2001
139 | Medicare | 1993–2000
140 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1998
141 | Medicaid | 1975, 1985–1989, 1991–1994, 1996–1998
142 | Department of Veterans Affairs | 1985, 1988–1989, 1991–1994, 1996–1999
143 | State mental health agency per capita expenditures | 1983, 1987
144 | Medicare | 1995–2002
145 | Medicaid | 1998, 2000–2001
146 | Health maintenance organizations | 1994, 1996–1997, 1999, 2001–2003