# Chartbook on Trends in the Health of Americans

## Population

### Age

The population age 65 and over is increasing at a faster rate than the total population.

From 1950 to 2005, the total resident population of the United States increased from 151 million to 296 million, representing an average annual growth rate of 1.2% (Figure 1). During the same period, the population 65 years of age and over grew on average 2.0% per year, increasing from 12 to 37 million persons. The population 75 years of age and over grew the fastest (on average, 2.8% per year), increasing from 4 to 18 million persons.

Figure 1 Total population and older population: United States, 1950–2050

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig01.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig01.ppt)

NOTE: See data table for data points graphed and additional notes.

SOURCE: U.S. Census Bureau.

Projections indicate that the rate of growth for the total population from now to 2050 will be slower, but older age groups will continue to grow more rapidly than the total population (1). By 2029, all of the baby boomers (those born in the post World War II period 1946–1964) will be age 65 years and over. As a result, the population age 65–74 years will increase from 6% to 10% of the total population between 2005 and 2030 (data table for Figure 1). As the baby boomers age, the population 75 years and over will also rise from 6% to 9% of the population by 2030 and continue to grow to 12% in 2050. By 2040 the population age 75 years and over will exceed the population 65–74 years of age.

#### Reference

1 Day JC. National population projections. U.S. Census Bureau. Available from: www.census.gov/population/www/pop-profile/natproj.html.

### Population in Group Quarters

About four million Americans live in institutions—the largest numbers in correctional institutions and nursing homes.

The U.S. Census Bureau defines two general categories of people residing in group quarters: the institutionalized population and the noninstitutionalized population. The institutionalized group quarters population includes people under formally authorized supervised care or custody in institutions. The noninstitutionalized group quarters population includes people in settings such as college dormitories, military quarters, group homes, and emergency or transitional shelters. The population living in group quarters is diverse and often has specialized health needs. Some segments of the group quarters population, such as college students or Armed Forces personnel living in barracks are relatively healthy. Other populations such as nursing home, mentally ill or disabled group home, and shelter residents might have disabilities or conditions requiring medical care and may need assistance or supervision with activities of daily living or instrumental activities of daily living (SeeAppendix II, Group quarters).

In 2000, the most recent year for which estimates are available, about 2.8% of the U.S. population, or 7.8 million people, lived in group quarters. About one-half of group quarters residents lived in institutional settings such as nursing homes, long-stay hospitals, and correctional facilities and the other half lived in noninstitutionalized group quarters residences (Figure 2).

Figure 2 Population in group quarters, by type of setting: United States, 1990 and 2000

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig02.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig02.ppt)

NOTES: Other institutions include hospital or wards, hospices, and schools for the handicapped. See data table for data points graphed and additional notes.

SOURCE: U.S. Census Bureau.

Between 1990 and 2000, the institutionalized population increased by 22% because the number of people in correctional institutions almost doubled (from 1.1 million to 2.0 million). This increase is largely due to changes in sentencing guidelines, increases in illegal drug use, and a more punitive approach to crime reduction (Table 2) (1).

During the same period, the noninstitutionalized group quarters population grew by 11%. This increase was fueled by the population residing in group homes, which more than doubled between 1990 and 2000. Group homes include community-based homes for the mentally ill, mentally retarded, physically handicapped, and drug/alcohol halfway houses not operated for correctional purposes. They also include some assisted living facilities and group homes for dementia patients.

Data presented in Health, United States come from more than 60 different data sets and although most are nationally representative, because of methodological or cost issues many of them represent only the civilian or the civilian noninstitutionalized populations and exclude institutionalized people.Appendix I, Data Sources, describes the population that each data set represents.

#### Reference

1 Golembeski C, Fullilove R. (2005). Criminal (In)justice in the city and its associated health consequences. Am J Public Health.

### Race and Ethnicity

The percentage of Americans who identify themselves as Hispanic or Asian continues to increase.

Changes in the racial and ethnic composition of the population have important consequences for the Nation's health because many measures of disease and disability differ significantly by race and ethnicity. One of the overarching goals of U.S. public health policy is elimination of racial and ethnic disparities in health.

Diversity has long been a characteristic of the U.S. population, but the racial and ethnic composition of the Nation has changed over time. In recent decades, the percentage of the population that is of Hispanic origin or Asian has more than doubled (data table for Figure 3). In 2005, nearly 30% of adults and almost 40% of children identified themselves as Hispanic, black, Asian, American Indian or Alaska Native, or Native Hawaiian or Other Pacific Islander.

Figure 3 Population in selected race and Hispanic origin groups, by age: United States, 1980–2005

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig03.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig03.ppt)

^1^Not Hispanic.

NOTES: Persons of Hispanic origin may be of any race. Race data for 2005 are not directly comparable with data for 1980 and 1990. Individuals could report only one race in 1980 and 1990, and more than one race in 2005. Persons who selected only one race in 2005 are included in single-race categories; persons who selected more than one race in 2005 are shown as having 2 or more races and are not included in single-race categories. In 1980 and 1990 the Asian category includes Asian and Native Hawaiian or Other Pacific Islander; in 2005, this category includes only Asian. See data table for data points graphed and data for Native Hawaiian or Other Pacific Islander.

SOURCE: U.S. Census Bureau.

In the 1980 and 1990 decennial censuses, Americans could choose only one racial category to describe their race (1). Beginning with the 2000 census, the question on race was modified to allow the choice of more than one racial category. Although overall, a small percentage of persons of non-Hispanic origin selected two or more races in 2005, the percentage of children described as being of more than one race was more than twice as high as the percentage of adults (Figure 3). The number of American adults identifying themselves or their children as multiracial is expected to increase in the future (2).

The percentage of persons reporting two or more races varies considerably among racial groups. For example, the percentage of persons reporting a specified race in combination with one or more additional racial groups was 1.6% for white persons and 35.7% for American Indian or Alaska Native persons in 2005 (3).

#### References

1 Grieco EM, Cassidy RC. Overview of race and Hispanic origin. Census 2000 brief. U.S. Census Bureau. March 2001.
2 Waters MC. (2000). Immigration, intermarriage, and the challenges of measuring racial/ethnic identities. Am J Public Health.
3 U.S. Census Bureau. Monthly postcensal resident population, by single year of age, sex, race, and Hispanic origin. Available from: www.census.gov/popest/national/asrh/2004_nat_res.html [data for July 1, 2005].

### Poverty

The poverty rate has increased in recent years among people under age 65.

Children and adults in families with incomes below or near the federal poverty level have worse health than those with higher incomes (seeAppendix II, Poverty for a definition of the federal poverty level). Although, in some cases, illness can lead to poverty, more often poverty causes poor health by its connection with inadequate nutrition, substandard housing, exposure to environmental hazards, unhealthy lifestyles, and decreased access to and use of health care services (1).

In 2004, the overall percentage of the U.S. population living in poverty was 12.7%, up from 11.3% in 2000 (2). Poverty rates for children under 18 years of age and working-age adults have increased since 2000, whereas the percentage of people age 65 years and over living in poverty has declined since 2002.

Starting in 1974, children have been more likely than either working-age or older adults to be living in poverty (Figure 4). In 2004, 13 million children (17.8%) lived in poverty and another 16 million children (21.4%) were classified as near-poor with family income between 100% and less than 200% of the poverty level (data table for Figure 5).

Figure 4 Poverty by age: United States, 1966–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig04.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig04.ppt)

NOTES: Data shown are the percentage of persons with family income below the poverty level. See data table for data points graphed and additional notes.

SOURCE: U.S. Census Bureau, Current Population Survey.

Figure 5 Low income by age, race, and Hispanic origin: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig05.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig05.ppt)

NOTES: Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Persons of Hispanic origin may be of any race. Black and Asian races include persons of Hispanic and non-Hispanic origin. See data table for data points graphed and additional notes.

SOURCE: U.S. Census Bureau, Current Population Survey.

Prior to 1974, persons 65 years of age and over were more likely to live in poverty than people of other ages. With the availability of inflation-adjusted government social insurance programs such as Social Security and Supplemental Security Income, the poverty rate of older adults declined rapidly until 1974 and continued to decline gradually to 9.7% in 1999 (3). In 2004, 3.5 million persons age 65 years and over or 9.8% of older adults lived in poverty. An additional 10 million were near-poor (data table for Figure 5).

At all ages, a higher percentage of Hispanic and black persons than non-Hispanic white persons were poor (Figure 5). In 2004, 29%–34% of Hispanic and black children were poor compared with 10%–11% of Asian and non-Hispanic white children. Similarly, among persons 65 years of age and over, almost one-fifth of Hispanic and one-quarter of black persons were poor, compared with 8% of non-Hispanic white persons and 14% of Asians. In 2002–2004, nearly one-quarter of American Indian or Alaska Native persons lived in poverty (estimate based on 3 years of data) (2).

#### References

1 Pamuk E, Makuc D, Heck K, Reuben C, Lochner K. Socioeconomic Status and Health Chartbook. Health, United States, 1998. Hyattsville, MD: National Center for Health Statistics. 1998.
2 DeNavas-Walt C, Proctor B, Hill LC. Income, poverty, and health insurance coverage in the United States: 2004. Current population reports, series P-60 no 229. Washington, DC: U.S. Government Printing Office. 2005. Available from: www.census.gov/prod/2005pubs/p60-229.pdf.
3 Hungerford T, Rassette M, Iams H, Koenig M. (2001–2002). Trends in the economic status of the elderly. Social Security Bulletin.

## Health Insurance and Expenditures

### Health Insurance at the Time of Interview

Between 1999 and 2004, the percentage of people under age 65 with no health insurance coverage at a given point in time has remained between 16% and 17%, whereas the percentage with private health insurance has declined and public programs have expanded to fill in some of the gaps.

Health insurance coverage is an important determinant of access to health care (1). Uninsured children and adults under 65 years of age are substantially less likely to have a usual source of health care or a recent health care visit than their insured counterparts (Tables 76, 77, 79, and 80). Uninsured people are more likely to forego needed health care due to cost concerns (Table 78). The major source of coverage for persons under 65 years of age is private employer-sponsored group health insurance. Private health insurance may also be purchased on an individual basis, but is generally more costly and provides less adequate coverage than group insurance. Public programs such as Medicaid and the State Children's Health Insurance Program (SCHIP) provide coverage for many low-income children and adults. Almost all adults age 65 and over are covered by the Medicare program, resulting in very few older adults without health insurance. Medicare enrollees may have additional private or public coverage to supplement their Medicare benefit package.

Between 1984 and 1994, private coverage declined among persons under 65 years of age, while Medicaid coverage and the percentage with no health insurance increased (Figure 6). After rising to 73% in 1999, the percentage with private health insurance decreased reaching 69% between 2002 and 2004. This decrease was offset by an increase in the percentage with Medicaid, resulting in little change in the percentage uninsured.

Figure 6 Health insurance coverage at the time of interview among persons under 65 years of age: United States, 1984–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig06.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig06.ppt)

NOTE: See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### Reference

1 Institute of Medicine. Committee on the consequences of uninsurance. Series of reports: Coverage matters: Insurance and health care; Care without coverage; Health insurance is a family matter; A shared destiny: Community effects of uninsurance; Hidden costs, value lost: Uninsurance in America. Washington, DC: National Academy Press. 2001–2003.

### Length of Time Without Health Insurance

Persons of Mexican origin were more likely than those in other race/ethnicity groups to be uninsured for more than 12 months.

Many people under age 65, particularly those with low incomes, do not have health insurance coverage consistently throughout the year. Reasons for discontinuities in coverage may include loss or change of employment and financial reverses, divorce, births and other changes in life circumstances, and migration between states. Respondents to the National Health Interview Survey (NHIS) were asked whether they had health insurance at the time of their interview and the type of coverage. Those covered by health insurance at the time of interview were asked whether there was any time during the 12 months prior to the interview when they did not have health insurance. People who were uninsured at the time of interview were asked how long it had been since they last had health coverage. These questions provide estimates of the percentage of persons without coverage at a point in time (Figure 6), as well as estimates of the percentage without coverage for different lengths of time (Figure 7).

Figure 7 Uninsured for at least part of the 12 months prior to interview among persons under 65 years of age, by length of time uninsured and selected characteristics: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig07.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig07.ppt)

NOTES: Persons of Hispanic origin may be of any race. Asian and American Indian or Alaska Native races include persons of Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

In 2004, 20% of people under 65 years of age reported being uninsured for at least part of the 12 months prior to interview. Among those who reported any time without insurance coverage during the 12 months prior to interview, the majority reported being uninsured for more than 12 months. About 11% of persons under 65 years reported being uninsured for more than 12 months, 8% reported being uninsured for any period up to 12 months, and 1% reported being uninsured and had missing data for the length of time they were uninsured (data table for Figure 7).

Children under 18 years of age were less likely to be uninsured than were adults, because low-income children are eligible for public programs such as SCHIP, designed specifically for them. The percentage of adults under 65 years of age without health insurance coverage decreased with age (Figure 7). In 2004, adults 18–24 years of age were more likely than adults age 55–64 years to lack coverage for at least part of the 12 months prior to interview (36% compared with 13%). About 20% of persons 18–24 years of age lacked coverage for more than 12 months.

People with family income below or near the poverty level were almost three times as likely to have no health insurance coverage for at least part of the 12 months prior to interview as those with family income twice the poverty level or higher, and were more than three times as likely to be uninsured for more than 12 months. Persons of Mexican origin were more likely than those in any other race/ethnicity group to be uninsured for at least part of the 12 months prior to interview. In 2004, 41% of Mexican-origin persons lacked coverage for at least part of the 12 months prior to interview with 32% of Mexican-origin persons lacking coverage for more than 12 months.

### Health Care Expenditures

In 2004, the United States spent $1.9 trillion on health care, comprising 16% of its Gross Domestic Product.

In 2004, the United States spent 16% (up from 14% in 2000) of its Gross Domestic Product (GDP) on health care, a greater share than any other developed country for which data are collected by the Organisation of Economic Co-operation and Development (Figure 8 and Tables 119 and 120).

Figure 8 National health expenditures as a percentage of Gross Domestic Product: United States, 1960–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig08.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig08.ppt)

NOTE: See data table for data points graphed and additional notes.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Accounts.

In 2004, the United States spent $1.9 trillion on health care, an average of $6,280 per person (Table 120). Personal health care expenditures, a component of national health expenditures that includes spending for hospital care, physician services, nursing home care, dental care, and other types of medical care accounted for 83% of national health expenditures in 2004. The remaining 17% was spent on administration, government public health activities, research, and structures and equipment (Table 123) (1).

Overall, private health insurance paid for 36% of total personal health expenditures in 2004, the federal government 34%, state and local government 11%, and out-of-pocket payments accounted for 15% (Figure 9). Since 1980, the share of total expenditures paid out-of-pocket declined by 12 percentage points (Table 124). This decline resulted from an expansion of benefits in both private health insurance plans and in government programs. Despite the decline in the share of health care expenditures paid out-of-pocket, the inflation in health care costs over recent years means that consumers may still have significant out-of-pocket expenditures for their health care.

Figure 9 Personal health care expenditures, by source of funds and type of expenditures: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig09.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig09.ppt)

NOTE: See data table for data points graphed and additional notes.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Accounts.

In 2004, 37% of personal health care expenditures were for hospital care, 26% for physician care, 12% for prescription drugs, 7% for nursing home care, and the remaining 18% for other personal health care, including visits to nonphysician medical providers, medical supplies, and other health services (Figure 9). Since 1980, the share of total personal health care expenditures devoted to hospital care has declined by 9 percentage points and the prescription drug expenditure share has doubled, reflecting the shift in health care from inpatient to ambulatory care settings and the increasing contribution of prescription drugs to health care services and spending (Table 123).

#### Reference

1 Smith C, Cowan C, Heffler S, Catlin A. (2006). National health spending in 2004: recent slowdown led by prescription drug spending. Health Aff.

## Health Risk Factors

### Cigarette Smoking

Fewer Americans are smoking, but nearly one-fifth of women and one-quarter of men and high school students still are current smokers, as are 10% of pregnant women.

Smoking is associated with a significantly increased risk of heart disease, stroke, lung and other types of cancer, and chronic lung diseases (1). Decreasing cigarette smoking among adolescents and adults is a major public health objective for the Nation. Preventing smoking among teenagers and young adults is critical because smoking usually begins in adolescence (2). Smoking during pregnancy contributes to elevated risk of miscarriage, premature delivery, and having a low birthweight infant (3).

Following the first Surgeon General's Report on smoking in 1964, cigarette smoking declined sharply for men and at a slower pace for women (Figure 10). Since 1990, the percentage of men and women who smoke has declined more slowly. By 2004, 23% of men and 19% of women were smokers. Cigarette smoking by adults continues to be strongly associated with educational attainment. Adults with less than a high school education were almost three times as likely to smoke as those with a bachelor's degree or more education (Table 64).

Figure 10 Cigarette smoking among men, women, high school students, and mothers during pregnancy: United States, 1965–2005

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig10.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig10.ppt)

NOTES: Estimates for men and women are age adjusted. Cigarette smoking is defined as: (for men and women 18 years of age and over) at least 100 cigarettes in lifetime and now smoke every day or some days; (for students in grades 912) 1 or more cigarettes in the 30 days preceding the survey; and (for mothers with a live birth) during pregnancy. See data table for data points graphed, standard errors, and additional notes.

SOURCES: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey (data for men and women); National Vital Statistics System (data for mothers during pregnancy); National Center for Chronic Disease Prevention and Health Promotion, Youth Risk Behavior Survey (data for high school students).

Cigarette smoking among high school students in grades 9–12 decreased between 1997 and 2005 after increasing in the early 1990s. In 2005, 8% of high school students had used smokeless tobacco, 14% had smoked cigars, and 9% had smoked frequently in the past 30 days (4).

Among mothers with a live birth, the percentage reporting on the birth certificate that they smoked cigarettes during pregnancy declined between 1989 and 2004 from 20% to 10%. Maternal smoking has declined for all racial and ethnic groups, but differences among these groups persist (Table 12).

#### References

1 U.S. Department of Health and Human Services. The health consequences of smoking: A report of the Surgeon General. Atlanta, GA: Centers for Disease Control and Prevention; 2004. Available from: www.cdc.gov/tobacco/sgr/sgr_2004/index.htm.
2 U.S. Department of Health and Human Services. Preventing tobacco use among young people: A report of the Surgeon General. Atlanta, GA: Centers for Disease Control and Prevention; 1994. Available from: www.cdc.gov/tobacco/sgr/sgr_1994/.
3 Mathews TJ. Smoking during pregnancy in the 1990s. National vital statistics reports 2001;49(7). Hyattsville, MD: National Center for Health Statistics. 2001. Available from: www.cdc.gov/nchs/data/nvsr/nvsr49/nvsr49_07.pdf.
4 Centers for Disease Control and Prevention. (2006). Youth Risk Behavior Surveillance—United States, 2005. MMWR.

### Binge Drinking and Current Marijuana Use Among High School Students

In 2005, 30% of high school students in grades 11–12 reported binge drinking and 22% reported marijuana use in the past 30 days.

Binge drinking and marijuana use among high school students have serious consequences. Alcohol use has been related to academic difficulties, social problems, risky sexual behavior, and motor vehicle accidents (1). Some studies have found that high school students who use marijuana get lower grades and are less likely to graduate than students who do not use marijuana (2). Tracking changes in binge drinking and marijuana use is important for evaluating efforts to prevent these behaviors among adolescents.

Estimates from the 1991 and 2003 Youth Risk Behavior Surveys are presented for students in grades 9–10, and from the 1993 and 2005 surveys for students in grades 11–12. Presentation of these years of data shows changes in binge drinking and marijuana use as students progress through high school, as well as changes in these behaviors over a 12-year period. Binge drinking was measured by asking students if they drank five or more drinks of alcohol in a row on one or more of the 30 days preceding the survey and current marijuana use by asking students if they used marijuana one or more times during the 30 days preceding the survey.

Between 1991–1993 and 2003–2005, binge drinking by male students decreased, while binge drinking by female students remained relatively stable (Figure 11). Among male students, binge drinking increased markedly between grades 9–10 and grades 11–12 in both time periods. Among female students, binge drinking increased between grades 9–10 and grades 11–12 in 1991–1993, but showed little change by grade level in 2003–2005. In 2005, 33% of male students and 27% of female students in grades 11–12 reported binge drinking in the past 30 days.

Figure 11 Binge drinking and current marijuana use among high school students, by sex, grade level, and year: United States, 1991,1993, 2003, and 2005

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig11.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig11.ppt)

NOTES: Binge drinking is drinking five or more drinks of alcohol in a row on one or more of the 30 days preceding the survey. Current marijuana use is using marijuana one or more times during the 30 days preceding the survey. See data table for data points graphed and standard errors.

SOURCE: Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Youth Risk Behavior Survey.

Between 1991–1993 and 2003–2005, current marijuana use increased among students in grades 9–10, but marijuana use remained unchanged among students in grades 11–12 (data table for Figure 11). Marijuana use increased markedly among both male and female students between grades 9–10 and grades 11–12 in 1991–1993, but showed little change by grade level in 2003–2005 (Figure 11). Marijuana use by students in grades 9–10 in 2003 was similar to marijuana use by students in grades 11–12 ten years earlier. In 2005, 25% of male students and 19% of female students in grades 11–12 reported marijuana use in the past 30 days.

#### References

1 Substance Abuse and Mental Health Services Administration. Consequences of underage alcohol use. Available from: ncadi.samhsa.gov/govpubs/rpo992/.
2 National Institute on Drug Abuse. InfoFacts: Marijuana. Available from: www.drugabuse.gov/Infofacts/marijuana.html/.

### Physical Activity

Most adults do not exercise as much as recommended, with people living in or near poverty less likely to engage in regular leisure-time physical activity than those with higher family income.

Benefits of regular physical activity include reduced risks of premature mortality, coronary heart disease, diabetes, colon cancer, hypertension, and osteoporosis. Regular physical activity also improves symptoms associated with musculoskeletal conditions and mental health conditions such as depression and anxiety. In addition, physical activity can enhance physical functioning and aid in weight control (1). National recommendations are for adults to engage in at least 30 minutes of moderate physical activity on most days of the week. Additional recommendations for physical activity target older age groups and weight loss or weight maintenance goals (2).

In the National Health Interview Survey, adults are asked about the frequency and duration of leisure-time physical activity. Adults classified as having regular leisure-time physical activity reported at least 20 minutes of vigorous activity 3 or more sessions per week or at least 30 minutes of light/moderate activity 5 or more sessions per week. The percentage of adults who engaged in leisure-time physical activity has remained stable in recent years (Table 72). In 2004, 30% of adults engaged in regular leisure-time activity. Regular leisure-time activity was more common among younger adults than older adults and more common among men than women.

Regular leisure-time physical activity levels vary by poverty and race and ethnicity (Figure 12). Adults living in families with income more than twice poverty were about 60% more likely than lower-income adults to engage in regular leisure-time activity (Table 72). Within family income groups, non-Hispanic white adults were more likely than Hispanic and non-Hispanic black adults to report regular leisure-time physical activity. Among adults living in families with income less than twice the poverty level, 24% to 25% of non-Hispanic white adults compared with 16% to 18% of Hispanic and non-Hispanic black adults reported regular leisure-time physical activity (percents are age adjusted).

Figure 12 Regular leisure-time physical activity among adults 18 years of age and over, by percent of poverty level, race and Hispanic origin: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig12.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig12.ppt)

NOTES: Data are for the civilian noninstitutionalized population and are age adjusted. Adults classified with regular leisure-time physical activity reported 3 or more sessions per week of vigorous activity of at least 20 minutes duration or 5 or more sessions per week of light/moderate activity lasting at least 30 minutes in duration. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### References

1 U.S. Department of Health and Human Services. Physical activity and health: A report of the Surgeon General. Atlanta, GA: Centers for Disease Control and Prevention. 1996. Available from: www.cdc.gov/nccdphp/sgr/sgr.htm.
2 U.S. Department of Health and Human Services and U.S. Department of Agriculture. Dietary Guidelines for Americans, 2005. Available from: www.healthierus.gov/dietaryguidelines/.

### Overweight and Obesity

Two-thirds of American adults are overweight and one-third are obese.

Surplus body weight is associated with excess morbidity and mortality (1). Among adults, overweight and obesity elevate the risk of heart disease, diabetes, and some types of cancer. Overweight and obesity also increase the severity of disease associated with hypertension, arthritis, and other musculoskeletal problems (2). Additionally, obesity has serious health consequences among younger persons. Among children and adolescents, obesity increases the risk of high cholesterol, liver abnormalities, diabetes, and becoming an overweight adult (3). Diet, physical activity, genetic factors, environment, and health conditions all contribute to overweight in children and adults. The potential health benefits from reduction in the prevalence of overweight and obesity are of significant public health importance.

The prevalence of overweight and obesity changed little between the early 1960s and 1976–1980 (Figure 13). Findings from the 1988–1994 and 1999–2004 National Health and Nutrition Examination Surveys, however, showed substantial increases in overweight among adults. The upward trend in overweight since 1980 reflects primarily an increase in the percentage of adults 20–74 years of age who are obese. In 2003–2004, 67% of adults in that age group were overweight with 34% obese (age adjusted). Since 1960–1962, the percentage of adults who were overweight but not obese has remained steady at 32%–34% (age adjusted).

Figure 13 Overweight and obesity, by age: United States, 1960–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig13.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig13.ppt)

NOTES: Estimates for adults are age adjusted. For adults: overweight including obese is defined as a body mass index (BMI) greater than or equal to 25, overweight but not obese as a BMI greater than or equal to 25 but less than 30, and obese as a BMI greater than or equal to 30. For children: overweight is defined as a BMI at or above the sex- and age-specific 95th percentile BMI cut points from the 2000 CDC Growth Charts: United States. Obese is not defined for children. See data table for data points graphed, standard errors, and additional notes.

SOURCES: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Examination Survey and National Health and Nutrition Examination Survey.

The percentage of children (6–11 years of age) and adolescents (12–19 years of age) who are overweight has risen since 1976–1980. In 2003–2004, 17%–19% of children and adolescents were overweight.

The prevalence of obesity varies among adults by sex, race, and ethnicity (Table 73). In 2001–2004, 30% of men and 34% of women 20–74 years of age were obese (age adjusted). The prevalence of obesity among women differed significantly by racial and ethnic group. In 2001–2004, one-half of non-Hispanic black women were obese compared with nearly one-third of non-Hispanic white women. In contrast, the prevalence of obesity among men was similar by race and ethnicity.

#### References

1 National Institutes of Health. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: The evidence report. NIH Pub. No. 98–4083. 1998. Available from: www.nhlbi.nih.gov/guidelines/obesity/ob_gdlns.htm.
2 U.S. Department of Health and Human Services. The Surgeon General's call to action to prevent and decrease overweight and obesity. Rockville, MD: U.S. Department of Health and Human Services; 2001. Available from: www.surgeongeneral.gov/topics/obesity/.
3 Dietz WH. (1998). Health consequences of obesity in youth: Childhood predictors of adult disease. Pediatrics.

### Untreated Dental Caries

Throughout the period 1971–1974 to 1999–2002, children of Mexican origin and non-Hispanic black children had a higher prevalence of untreated dental caries than non-Hispanic white children.

Dental caries, or tooth decay, is caused by bacteria and is one of the most common chronic diseases in young children. If left untreated, it can cause pain, infection, and even loss of teeth (1). Good oral hygiene, including tooth brushing, flossing, regular professional cleaning, and the application of dental sealants can help prevent damage caused by dental caries. The progression of caries can be stopped by treatment. Once destroyed, tooth structure does not regenerate. Although primary or baby teeth are eventually replaced by permanent teeth, early childhood caries is a major predictor of caries in later years (2).

Between 1971–1974 and 1988–1994, the percentage of children with untreated dental caries declined, especially among children 6–17 years of age. This decline was largely due to fluoridation of the water supply and to topically applied fluoride treatments (1,2,3). Since 1988–1994, the percentage of children with untreated dental caries has not significantly changed, except for a decrease among non-Hispanic black children 6–17 years of age (data table for Figure 14).

Figure 14 Untreated dental caries among children, by age, race and Hispanic origin: United States, 1971–2002

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig14.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig14.ppt)

NOTES: Persons of Mexican origin may be of any race. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

Throughout the period 1971–1974 to 1999–2002, children of Mexican origin and non-Hispanic black children had a higher prevalence of untreated caries than non-Hispanic white children (Figure 14). In 1999–2002, Mexican children 6–17 years of age had untreated dental caries almost twice as frequently as non-Hispanic white children of the same age. Non-Hispanic black school-age children were 58% more likely to have untreated dental caries than non-Hispanic white children.

#### References

1 Centers for Disease Control and Prevention. Surveillance for dental caries, dental sealants, tooth retention, edentulism, and enamel fluorosis—United States, 1988–1994 and 1999–2002. MMWR 54(SS-3):1–44. 2005. Available from: www.cdc.gov/mmwr/preview/mmwrhtml/ss5403a1.htm.
2 National Institutes of Health Consensus Development Conference Statement. (2001). Diagnosis and management of dental caries throughout life. J Dent Educ.
3 Centers for Disease Control and Prevention. Ten great public health achievements—United States, 1900–1999. MMWR 48(12):241–3. 1999. Available from: www.cdc.gov/mmwr/preview/mmwrhtml/00056796.htm.

## Morbidity and Limitation of Activity

### Three or More Chronic Conditions

Poverty was strongly associated with having three or more chronic conditions among adults age 45–74 years in 2004.

Many studies of adult health have shown a strong association between poverty and a wide array of chronic health conditions (1). Given the association between poverty and the risk factors for many chronic health conditions, it is not surprising that adults with low incomes more often report multiple serious health conditions than adults with higher incomes. The relationship between poverty and serious health problems reflects both the effect of low income on health and the effect of poor health on income (1,2).

Data from the National Health Interview Survey were used to assess chronic health conditions of adults age 45 years and over living in the community. Adults with three or more chronic conditions included persons ever diagnosed with three or more of the following conditions: hypertension, heart disease, stroke, emphysema, diabetes, cancer, arthritis, or asthma. Among adults ever diagnosed with asthma, only those who reported currently having asthma were considered to have a chronic condition.

The percentage of adults with three or more chronic conditions increased with age in 2004 from 7% of adults 45–54 years of age to 36% of adults 75 years of age and over. Among adults 45–74 years of age, the percentage of persons reporting three or more chronic conditions rose as income declined (Figure 15). Among adults 75 years of age and over, the percentage of persons with three or more chronic conditions did not vary significantly by income. Adults 55–64 years of age in the lowest income group (below 100% of the poverty level) were as likely to have three or more chronic conditions as older adults 75 years of age and over in the highest income group (400% or more of the poverty level).

Figure 15 Three or more chronic conditions among adults 45 years of age and over, by age and percent of poverty level: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig15.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig15.ppt)

NOTES: Adults who had ever been told by a physician they had 3 or more of the following conditions: hypertension, heart disease, stroke, emphysema, diabetes, cancer, arthritis and related diseases, or current asthma. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### References

1 Pamuk E, Makuc D, Heck K, Reuben C, Lochner K. Socioeconomic Status and Health Chartbook. Health, United States, 1998. Hyattsville, MD: National Center for Health Statistics. 1998.
2 Freidland RB. Multiple chronic conditions. Data Profiles, Challenges for the 21st Century: Chronic and Disabling Conditions: Number 12. Georgetown University Center on an Aging Society. November 2003.

### Limitation of Activity: Children

Conditions associated with learning, emotional, and behavioral problems are leading causes of activity limitation among children.

Limitation of activity due to chronic physical, mental, or emotional conditions is a broad measure of health and functioning that gauges a child's ability to engage in major age-appropriate activities and is related to a child's need for special educational and medical services. The National Health Interview Survey identifies children with activity limitation through questions about specific limitations in activities such as play, self-care, walking, memory, and other activities, and the current use of special education or early intervention services. Estimates of the number of children with an activity limitation may differ depending on the type of limitations included and the methods used to identify them (1).

Between 1997 and 2004, the share of children with activity limitation was 7% (Table 58). In 2003–2004, the percentage of school-age children with activity limitation (8%) was double the percentage of preschoolers with limitation (4%) primarily due to the large number of school-age children who were identified as limited solely by their participation in special education (2).

In 2003–2004, chronic health conditions causing activity limitation in children varied by age (Figure 16). Speech problems, mental retardation, and asthma were the leading causes of activity limitation among preschool children. Learning disability and Attention Deficit/Hyperactivity Disorder (ADHD or ADD) were the leading causes of activity limitation among all school-age children. Among younger school-age children, speech problems were another important cause of activity limitation and among older school-age children, other mental, emotional, and behavioral problems were an important cause.

Figure 16 Selected chronic health conditions causing limitation of activity among children, by age: United States, 2003–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig16.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig16.ppt)

NOTES: Children with more than one chronic health condition causing activity limitation are counted in each category. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### References

1 Newacheck PW, Strickland B, Shonkoff JP, et al. (1998). An epidemiologic profile of children with special health care needs. Pediatrics.
2 Federal Interagency Forum on Child and Family Statistics. America's Children: Key National Indicators of Well-Being, 2005. Washington, D.C. 2005.

### Limitation of Activity: Working-Age and Older Adults

Arthritis and other musculoskeletal conditions are the most frequently reported cause of activity limitation among both working-age and older adults.

Chronic physical, mental, and emotional conditions can limit the ability of adults to carry out important activities such as working and doing everyday household chores. With advancing age, an increasing percentage of adults experience limitation of activity. Estimates of the number of working-age and older adults with limitation of activity are important for determining current and future types of health care needs and associated costs (1).

Between 1997 and 2004, the percentage of working-age adults 18–64 years of age reporting an activity limitation caused by a chronic health condition remained relatively stable (Table 58). In 2003–2004, the percentage of working-age adults who reported limitations ranged from 6% at age 18–44 years to 21% at age 55–64 years (2). Arthritis and other musculoskeletal conditions were the most frequently mentioned conditions causing limitation among working-age adults of all ages in 2003–2004 (Figure 17). Among adults 18–44 years of age, mental illness was the second leading cause of activity limitation followed by fractures or joint injury. Among adults 45–64 years of age, heart and circulatory conditions were the second leading cause of limitation. Other frequently mentioned conditions included mental illness and diabetes.

Figure 17 Selected chronic health conditions causing limitation of activity among working-age adults, by age: United States, 2003–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig17.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig17.ppt)

NOTES: Data are for the civilian noninstitutionalized population. Persons may report more than one chronic health condition as the cause of their activity limitation. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Between 1997 and 2004, the percentage of adults 65 years of age and over in the noninstitutionalized population reporting an activity limitation caused by a chronic health condition declined slightly (Table 58). In 2003–2004, the percentage of older adults with limitation of activity ranged from 26% of 65–74 year olds to 62% of adults 85 years old and over (2). Arthritis and other musculoskeletal conditions were the most frequently mentioned chronic conditions causing limitation of activity (Figure 18). Heart and circulatory conditions were the second leading cause of limitations. Among adults 85 years and over, senility, vision conditions, and hearing problems were frequently mentioned causes of activity limitation.

Figure 18 Selected chronic health conditions causing limitation of activity among older adults, by age: United States, 2003–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig18.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig18.ppt)

NOTES: Data are for the civilian noninstitutionalized population. Persons may report more than one chronic health condition as the cause of their activity limitation. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### References

1 Guralnik JM, Fried LP, Salive ME. (1996). Disability as a public health outcome in the aging population. Annu Rev Public Health.
2 Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey, unpublished analysis.

## Health Care Utilization

### Dental Visit Among Children

Hispanic children 6–17 years of age are less likely to have a recent dental visit than children in other racial and ethnic groups.

The American Dental Association recommends that children see a dentist for the first time within 6 months of the appearance of the first tooth and no later than the child's first birthday (1). The American Academy of Pediatric Dentistry also recommends that all children should visit a dentist in their first year of life and every 6 months thereafter, or as indicated by the individual child's risk status or susceptibility to disease (2). Attitudes and habits established at an early age are critical in maintaining good oral health throughout life. Benefits of early dental intervention include assessment of risk status, analysis of fluoride exposure and feeding practices, such as excessive sugar consumption, and oral hygiene counseling.

Preschool children 2–5 years of age are less likely to have a recent dental visit than school-age children 6–17 years of age (Figure 19). On average, 54% of preschool-age children had a dental visit in the past year compared with 84% of school-age children in 2004 (data table for Figure 19). No difference in the recent use of dental visits among preschool-age children was noted by race and ethnicity.

Figure 19 Dental visit in the past year among children, by age, race and Hispanic origin: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig19.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig19.ppt)

NOTES: Asian race includes children of Hispanic and non-Hispanic origin. Data for Asian children 25 years of age are not shown because they are not reliable. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

In contrast to younger children, the proportion of school-age children with a recent dental visit varies by race and ethnicity (Figure 19). Among school-age children 6–17 years of age, Hispanic children had lower levels of recent dental visits than children in other racial and ethnic groups. Non-Hispanic black and Mexican-origin children were more likely to have untreated dental caries than non-Hispanic white children (Figure 14 and Table 75).

#### References

1 American Dental Association. ADA statement on early childhood caries. 2000. Available from: www.ada.org/prof/resources/positions/statements/caries.asp.
2 American Academy of Pediatric Dentistry. Guideline on periodicity of examination, preventive dental services, anticipatory guidance, and oral treatment for children. Available from: www.aapd.org/media/Policies_Guidelines/G_Periodicity.pdf.

### Influenza Vaccination: Adults 50 Years of Age and Over

Non-Hispanic black and Hispanic adults age 50 and over were less likely to receive influenza vaccinations than non-Hispanic white adults in 2003–2004.

Annual influenza vaccination can lessen the risk of hospitalization and death among persons 65 years of age and over and also prevent influenza-related complications for persons 18–64 years of age with medical conditions (1). In 2000, the Advisory Committee on Immunization Practices (ACIP) broadened the universal recommendations for influenza vaccination to include adults 50–64 years of age, in addition to adults 65 years of age and over, due to the high prevalence of chronic medical conditions in adults 50–64 years of age (2). In 2003–2004, about 64% of adults 50–64 years of age had one or more chronic medical conditions (3).

In 2003–2004, 65% of adults 65 years of age and over reported an influenza vaccination during the preceding 12 months, compared with 36% of adults 50–64 years of age (data table for Figure 20). Although influenza vaccination rates have increased for non-Hispanic and Hispanic population groups, substantial gaps persist by race and ethnicity (Table 83). Influenza vaccination coverage among adults 50–64 years of age was about 30% lower for non-Hispanic blacks and Hispanic persons than non-Hispanic white persons (Figure 20). Similarly, influenza vaccination rates among adults 65 years of age and over were about 30% lower for non-Hispanic blacks and Hispanic persons than for non-Hispanic whites.

Figure 20 Influenza vaccination during the past year among adults 50 years of age and over, by race and Hispanic origin: United States, 2003–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig20.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig20.ppt)

NOTES: Data are for the civilian noninstitutionalized population. Persons of Hispanic origin may be of any race. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### References

1 Hak E, Buskens E, van Essen GA, et al. (2005). Clinical effectiveness of influenza vaccination in persons younger than 65 years with high-risk medical conditions: the PRISMA study. Arch Intern Med.
2 Centers for Disease Control and Prevention. Prevention and Control of Influenza. (2000). Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR.
3 Centers for Disease Control and Prevention. National Center for Health Statistics, National Health Interview Survey, unpublished analysis.

### Emergency Department Visits for Falls

Falls are the reason for many emergency department visits, including about 20% of all emergency department visits for women age 85 years and over.

Falls are among the leading causes of injury for persons of all ages. They can result in fractures, sprains and strains, open wounds, and other injuries that require medical treatment and are a significant reason for emergency department (ED) visits (Table 88). Encouraging adults to exercise and improve their balance can help reduce the prevalence of falls among frail seniors. Making homes and playgrounds safer can reduce falls among young children (1,2).

Falls account for a large share of ED services. In 2002–2004, almost 8 million ED visits per year had falls recorded as their first-listed external cause of injury—accounting for 7% of all ED visits (data table for Figure 21). About 8% of ED visits for children under age 18 were fall-related. Among adults, the percentage of ED visits that were fall-related increased with age from 5% at 18–44 years to 18% for adults age 85 years and over.

Figure 21 Emergency department visits for falls, by sex and age: United States, 2002–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig21.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig21.ppt)

NOTES: Visits with a severe disposition for males 6574 years and females 44 years or younger have a relative standard error of 20%30%. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Ambulatory Medical Care Survey.

In 2002–2004, fall-related ED visit rates per 10,000 population were lowest among adults 18–64 years of age, higher among children and adults 65–74 years, and higher still among adults 75 years of age and over (data table for Figure 21). Fall visit rates for adults 85 years and over were almost 8 times that of adults 18–64 years of age.

ED visit rates due to falls vary by gender (Figure 21). Boys under 18 years of age had higher ED visit rates for falls than girls. Starting at age 45–64 years, women had higher rates than men.

ED visits for falls have varying outcomes. Whereas most fall visits resulted in the person being discharged home, 12% of all ED visits made for fall-related injuries were severe enough to result in hospitalization, transfer to another hospital or health care facility, or death in the ED. Among men and women age 85 and over, ED visits for falls were more likely to have a severe outcome than visits for younger persons. Fracture of the hip and other lower extremities are among the most common types of fall-related injuries that resulted in hospitalization among older adults (3). Loss of bone mass that occurs disproportionately in post-menopausal women may explain, in part, women's greater rate of hip fracture (4).

#### References

1 Chang JT, Morton SC, Rubenstein LZ, et al. (2004). Interventions for the prevention of falls in older adults: Systematic review and meta-analysis of randomized clinical trials. BMJ.
2 McDonald E, Girasek D, Gielen A. Home Injuries pp. 123–61 in K. Liller (Ed), Injury Prevention for Children and Adolescents. APHA: Washington, DC. 2006.
3 Roudsari BS, Ebel BE, Corso PS, Molinari NM, Koepsell TD. (2005). The acute medical costs of fall-related injuries among the U.S. older adults. Injury, Int. J Care Injured.
4 Stevens JA, Sogolow ED. (2005). Gender differences for non-fatal unintentional fall-related injuries among older adults. Injury Prevention.

### Visits to Physician Offices and Hospital Outpatient Departments

Physician office and hospital outpatient department visit rates were higher among women age 18–44 years than for men in that age group, but the gender difference disappears with age.

Americans of all ages visit physician offices and hospital outpatient departments (OPDs) to receive preventive and screening services, diagnosis and treatment of health conditions, medical counseling, and other types of ambulatory health care. In 2003–2004, there were, on average, one billion visits per year to physician offices and OPDs (data table for Figure 22). Many OPD clinics provide preventive services and primary care similar to services received in private physicians' offices. About 8% of visits were made in OPDs overall, but OPDs were more frequently used as sites of care for black persons than for white persons (Table 89).

Figure 22 Visits to physician offices and hospital outpatient departments, by sex and age: United States, 1997–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig22.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig22.ppt)

NOTE: See data table for data points graphed, standard errors, and additional notes.

SOURCES: Centers for Disease Control and Prevention, National Center for Health Statistics, National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey.

Data from the National Ambulatory Medical Care Survey and the National Hospital Ambulatory Medical Care Survey Outpatient Department component, which are abstracted from medical records, provide a snapshot of care from office-based physicians and OPDs. Between 1997–1998 and 2003–2004, physician and OPD visit rates fluctuated between 3.2 and 3.7 visits per person (data table for Figure 22). Visit rates increased with age with rates among adults 65 years of age and over were more than twice as high as rates among children and young adults.

In 2003–2004, women 18–64 years of age had higher visit rates than men, with the largest gender difference in visit rates occurring among adults 18–44 years of age (Figure 22). In this age group, visit rates for women were more than twice as high as for men, largely due to care associated with female reproduction. This gender difference narrows among middle-age adults and disappears among adults 65 years of age and over.

### Bariatric Procedures

The number of inpatient bariatric procedures among obese adults age 18–64 years has increased substantially since 1996–1998, with more than four-fifths of these procedures performed on women.

Almost one-third of American adults are obese (Table 73). Obesity has serious health consequences, including increased risk for hypertension, diabetes, osteoarthritis, sleep apnea, and heart disease (1). Because losing weight by dieting is often ineffective for long-term weight loss (2), bariatric procedures—including gastric bypass—have become an increasingly popular option for those who are morbidly obese.

Bariatric procedures are recommended for those who are morbidly obese (body mass index 40 or higher or body mass index 35 or higher with comorbid conditions (see Appendix II, Body Mass Index (BMI)). Bariatric procedures to treat obesity involve reducing the size of the stomach or bypassing part of the intestines. These approaches promote weight loss by reducing the body's ability to absorb food and increasing the sensation of fullness. Bariatric procedures usually result in substantial weight loss. On average, patients lose more than half of their body weight after the procedures (2). Many patients see a reversal or substantial improvement in many of the comorbidities associated with obesity, including diabetes, hypertension, and sleep apnea (2).

From 1996–1998 to 2002–2004, the average annual number of inpatient bariatric procedures among obese patients 18–64 years of age increased more than nine-fold, from about 10,000 to more than 100,000 (data table for Figure 23). In 2002–2004, there were about five times as many bariatric surgeries among women as men age 18–64 years (Figure 23). There were more than 60,000 bariatric procedures among adults 18–44 years of age in 2002–2004 and over 40,000 among those 45–64 years of age. Bariatric procedures may be performed on an inpatient or outpatient basis. These estimates include only inpatient procedures. Therefore, the total number of bariatric procedures performed is greater than the estimates presented here.

Figure 23 Average annual hospital inpatient gastric bypass and other bariatric procedures among adults 18–64 years of age with obesity, by sex and age: United States, 1999–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig23.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig23.ppt)

NOTES: Up to four procedures were coded for each hospital stay. Bariatric procedures were any-listed procedures. See data table for data points graphed, procedure codes, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Discharge Survey.

Bariatric procedures have many serious side effects and a reported mortality of approximately 1% in the year following the procedures (3). Between 1998 and 2003, 10% of hospitalizations in which gastric bypass was performed had a complication during the hospital stay (4). One-fifth of patients are hospitalized in the first year following their procedures and some patients experience serious complications including wound infection, bowel obstruction, and hernia (3). The long-term health consequences of the procedures are unknown. As more Americans undergo these procedures, a clearer picture of the risks and benefits of bariatric procedures will emerge.

#### References

1 National Institutes of Health. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: The evidence report. NIH Pub. No. 98–4083. 1998. Available from: www.nhlbi.nih.gov/guidelines/obesity/ob_gdlns.htm.
2 Buchwald H, Avidor Y, Braunwald E, Jensen MD, Pories W, Fahrbach K, Schoelles K. (2004). Bariatric surgery: A systematic review and meta-analysis. JAMA.
3 Zingmond DS, McGory ML, Ko CY. (2005). Hospitalization before and after gastric bypass surgery. JAMA.
4 Shinogle JA, Owings MF, Kozak LJ. (2005). Gastric bypass as treatment for obesity: Trends, characteristics, and complications. Obes Res.

## Mortality

### Life Expectancy

Life expectancy continues to increase, and the gap in life expectancy between males and females has been narrowing.

Life expectancy is a measure often used to gauge the overall health of a population. As a summary measure of mortality, life expectancy represents the average number of years of life that could be expected if current death rates were to remain constant. Shifts in life expectancy are often used to describe trends in mortality. Life expectancy at birth is strongly influenced by infant and child mortality. Life expectancy later in life reflects death rates at or above a given age and is independent of the effect of mortality at younger ages (1).

From 1900 through 2003, life expectancy at birth increased from 48 to 75 years for men and from 51 to 80 years for women (Figure 24). Life expectancy at age 65 has also increased since the beginning of the 20th century. Among men, life expectancy at age 65 rose from 12 to 17 years and among women from 12 to 20 years. In contrast to life expectancy at birth, which increased sharply early in the 20^th^ century, life expectancy at age 65 improved primarily after mid-century. Improved access to health care, advances in medicine, healthier lifestyles, and better health before age 65 are factors underlying decreased death rates among older Americans (2).

Figure 24 Life expectancy at birth and at 65 years of age, by sex: United States, 1900–2003

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig24.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig24.ppt)

NOTE: See data table for data points graphed and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System.

Athough the overall trend in life expectancy for the United States was upward throughout the 20th century, the gain in years of life expectancy for women generally exceeded that for men until the 1970s, widening the gap in life expectancy between men and women. After the 1970s, the gain in life expectancy for men exceeded that for women and the gender gap in life expectancy began to narrow. Between 1990 and 2003, the total gain in life expectancy for women was 1.3 years compared with 3.0 years for men, reflecting proportionately greater decreases in heart disease and cancer mortality for men than for women and proportionately larger increases in chronic lower respiratory diseases mortality among women (3).

#### References

1 Arriaga EE. (1984). Measuring and explaining the change in life expectancies. Demography.
2 Fried LP. (2000). Epidemiology of aging. Epidemiol Rev.
3 Arias E. United States life tables, 2003. National vital statistics reports. Hyattsville, MD: National Center for Health Statistics. 2006.

### Infant Mortality

Infant mortality rates have decreased for most racial and ethnic groups, but large disparities between the groups persist.

The infant mortality rate, the risk of death during the first year of life, is related to the underlying health of the mother, public health practices, socioeconomic conditions, and availability and use of appropriate health care for infants and pregnant women. Disorders related to short gestation and low birthweight, and congenital malformations are the leading causes of death during the neonatal period (less than 28 days of life). Sudden Infant Death Syndrome (SIDS) and congenital malformations rank as the leading causes of infant deaths during the postneonatal period (28 days through 11 months of life) (1).

In 2003, the infant mortality rate decreased to 6.9 infant deaths per 1,000 live births after increasing in 2002 for the first time in more than 40 years (Figure 25 and Table 22). The 2003 infant mortality rate was 76% lower than in 1950. During the period 1950–2003, substantial declines occurred for both neonatal and postneonatal mortality.

Figure 25 Infant, neonatal, and postneonatal mortality rates: United States, 1950–2003

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig25.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig25.ppt)

NOTES: Infant is defined as under 1 year of age, neonatal as under 28 days of age, and postneonatal as between 28 days and 1 year of age. See data table for data points graphed and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System.

Infant mortality rates have declined for most racial and ethnic groups, but large disparities between the groups remain (Table 19). During 2001–2003, the infant mortality rate was highest for infants of non-Hispanic black mothers (Figure 26). Infant mortality rates were also high among infants of American Indian or Alaska Native mothers and Puerto Rican mothers. Infants of mothers of Cuban origin had the lowest infant mortality rates.

Figure 26 Infant mortality rates, by detailed race and Hispanic origin of mother: United States, 2001–2003

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig26.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig26.ppt)

NOTES: Infant is defined as under 1 year of age. Persons of Hispanic origin may be of any race. Asian or Pacific Islander and American Indian or Alaska Native races include persons of Hispanic and non-Hispanic origin. See data table for data points graphed and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System, National Linked Birth/Infant Death Data Sets.

#### Reference

1 Heron MP, Smith BL. Deaths: Leading causes for 2003, forthcoming.

### Leading Causes of Death for All Ages

Mortality from heart disease, stroke, and unintentional injuries is substantially lower than in 1950.

In 2003, a total of 2.4 million deaths were reported in the United States (Table 31). The overall age-adjusted death rate was 42% lower in 2003 than in 1950. The reduction in overall mortality during the last half of the 20^th^ century was driven mostly by declines in mortality for such leading causes of death as heart disease, stroke, and unintentional injuries (Figure 27).

Figure 27 Death rates for leading causes of death for all ages: United States, 1950–2003

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig27.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig27.ppt)

NOTES: Estimates are age adjusted. Causes of death shown are the five leading causes of death for all ages in 2003. CLRD is chronic lower respiratory diseases. Starting with 1999 data, causes of death were coded according to ICD-10. See data table for data points graphed and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System.

In 2003, the age-adjusted death rate for heart disease, the leading cause of death, was 60% lower than the rate in 1950 (Table 36). The age-adjusted death rate for stroke, the third leading cause of death, declined 70% since 1950 (Table 37). Heart disease and stroke mortality are associated with risk factors such as high cholesterol, high blood pressure, smoking, and dietary factors. Other important factors include socioeconomic status, obesity, and physical inactivity. Factors contributing to the decline in heart disease and stroke mortality include better control of risk factors, improved access to early detection, and better treatment and care, including new drugs and expanded uses for existing drugs (1).

Overall age-adjusted death rates for cancer, the second leading cause of death, rose between 1960 and 1990 and then reversed direction (Table 38). Between 1990 and 2003 overall death rates for cancer declined 12%. The trend in the overall cancer death rate reflects the trend in the death rate for lung cancer (Table 39). Since 1970, the death rate for lung cancer for the total population has been higher than the death rate for any other cancer site.

Chronic lower respiratory diseases (CLRD) were the fourth leading cause of death in 2003. The age-adjusted death rate for CLRD in 2003 was 53% higher than the rate in 1980. CLRD mortality increased during the period 1980 to 1999. Since 1999, CLRD mortality has decreased slightly (Table 41).

The fifth leading cause of death in 2003 was unintentional injuries. Age-adjusted death rates for unintentional injuries declined during the period 1950–1992 (Table 29). Since 1992, the unintentional injury mortality rate has gradually increased. Despite recent increases, the death rate for unintentional injuries in 2003 was still 52% lower than the rate in 1950.

#### Reference

1 Centers for Disease Control and Prevention. (1999). Achievements in public health, 1990–1999: Decline in deaths from heart disease and stroke—United States, 1990–1999. MMWR.

## Special Feature: Pain

### Introduction: Prevalence and Duration of Pain among Adults in the Month Prior to Interview

More than one-quarter of American adults experienced pain that lasted a day or more during the month prior to interview.

Pain hurts—physically, mentally, emotionally, and at times financially. All persons experience pain at some time during their lives. It affects physical and mental functioning, and can profoundly affect quality of life. Treating it is often expensive, time-consuming, and sometimes extremely frustrating. In addition to the direct costs of treating pain—including medical practitioner and hospital visits for diagnosis and treatment, drugs, therapies, and other medical costs—it causes work-loss time, and loss of productivity and concentration at work or while conducting other activities (1,2). Because of these and other factors, the 106th U.S. Congress passed Title VI, Sec. 1603, of H.R. 3244, which declared the 10-year period beginning January 1, 2001, as the "Decade of Pain Control and Research."

The International Association for the Study of Pain (IASP) defines pain as "an unpleasant sensory and emotional experience associated with actual or potential tissue damage, or described in terms of such damage" (3). Pain is a symptom produced when inflammation or changes to the nervous system due to illness or injury are transmitted to the brain, producing a physical sensation that alerts the brain that damage has occurred. Generally, as the inflammation subsides or the wound heals the pain lessens and eventually goes away, although in some cases it does not. Pain can be constant or episodic, last for a minute or most of a lifetime, and can be dull or sharp, throbbing or piercing, localized or widespread, severe or less severe, and ultimately, tolerable or intolerable. Pain can have an undetectable or a nonphysical cause, making it hard to treat.

Pain is always subjective. Although it is a physical sensation, perceptions of pain are influenced by social, cultural, and psychological factors, producing different sensations in different people. Pain in older adults has been shown to be underreported, possibly because of a reluctance to report pain, resignation to the presence of pain, and skepticism about the beneficial effects of potential treatments (4). Perceptions of pain differ by the context in which it occurs; expectations about how much pain one "should" feel; anxiety and feelings about a loss of control that can increase pain; past pain experiences; coexisting physical and mental conditions; and many other factors (5). Research has shown that distracting patients in severe pain can lessen it, and that focusing on pain can make it worse.

Data from the 1999–2002 National Health and Nutrition Examination Survey show that more than one-quarter of Americans (26%) age 20 years and over reported that they had a problem with pain—of any sort—that persisted for more than 24 hours in duration in the month prior to interview (Figure 28). Adults age 45–64 years were the most likely to report pain lasting more than 24 hours (30%). Twenty-five percent of young adults age 20–44 reported pain, and adults age 65 years and over were the least likely to report pain (21%). Women reported pain more often than men, and non-Hispanic white adults reported pain more often than adults of other races and ethnicities. Adults living in families with income less than twice the poverty level reported pain more often than higher income adults.

Figure 28 Adults 20 years of age and over reporting pain in the month prior to interview, by selected characteristics: United States, 1999–2002

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig28.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig28.ppt)

NOTES: Respondents were asked to report pain that lasted more than 24 hours. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

Measures of pain prevalence are affected not only by how different people perceive pain, but whether it is reported at all. One factor in whether pain is considered salient enough to report is the duration of the pain that is experienced. Adults 20 years of age and over who reported pain in the month prior to interview (Figure 28) were asked a follow-up question about the duration of that pain. Nearly one-third of adults 20 years of age and over who reported pain said that it lasted less than 1 month, 12% reported pain that lasted 1–3 months, 14% reported pain that lasted 3 months to 1 year, and 42% reported pain that lasted more than 1 year (data table for Figure 29). Although persons age 65 years and over are less likely to report pain lasting 24 hours or more, 57% of older adults who reported pain indicated that the pain lasted for more than 1 year compared with 37% of adults 20–44 years of age who reported pain (Figure 29). Conversely, adults 20–44 years were considerably more likely to report relatively short-lived pain. Therefore the duration of pain (long- or short-lived) reported by different age groups may explain, in part, differences in pain reporting and pain prevalence by age.

Figure 29 Duration of pain among adults reporting pain, by age: United States, 1999–2002

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig29.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig29.ppt)

NOTES: Respondents who reported pain lasting more than 24 hours in duration in the month prior to interview (Figure 28) were asked a follow-up question about the duration of that pain. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

This Special Feature provides a general overview of pain experienced by adults in the United States. It focuses on common types of pain using data from several national data sources. Some data are collected during in-person interviews with the participant reporting the location, extent, duration, and severity of selected sites of pain. Because some types of pain persist, while other types recur more or less frequently, pain questions have different recall periods. For example, people are asked about any pain that lasted a day or more in the month prior to interview but about severe headaches and back pain during the 3-month period prior to interview. Prevalence estimates with different recall periods are not directly comparable. (See Technical Notes for pain questions and recall periods.)

Another way to gather information on pain is to ask respondents about use of medications to control severe pain, such as prescription narcotic drugs. Pain in individuals can be indirectly inferred from measures of health care utilization, for example, use of hospital procedures for pain reduction such as hip and knee replacement.

The Special Feature presents data on the prevalence and possible effects of pain in terms of health status and health care utilization measures, as well as some economic implications including ambulatory medical care expenditures for headache. The relationships between reported pain and race/ethnicity, gender, age, income level, and health status are complex and raise important issues for individuals, the health care system, and society at large. Focusing on pain prevalence and its effects for population subgroups may provide insight for public health initiatives and policies with the ultimate goal of reducing disparities in quality of life and level of functioning.

#### References

1 McCool WF, Smith T, Aberg C. (2004). Pain in Women's Health: A multi-faceted approach toward understanding. J Midwivery Womens Health.
2 Luo X, Pietrobon R, Sun SX, Liu GG, Hey L. (2004). Estimates and patterns of direct health care expenditures among individuals with back pain in the United States. Spine.
3 IASP website. Available from: www.iasp-pain.org/terms-p.html#Pain.
4 Yong HH, Gibson SJ, de L Horne DJ, Helms RD. (2001). Development of a pain attitudes questionnaire to assess stoicism and cautiousness for possible age differences. Journal of Gerontology.
5 Hansen GR, Streltzer J. (2005). The Psychology of Pain. Emerg Med Clin of N Am.

### Low Back, Migraine/Severe Headache, Neck, and Face Pain

The prevalence of low back pain, migraine/severe headache, neck, and face pain varies significantly by age.

Pain occurs in many different parts of the body, each with its own prevalence and presentation patterns. Low back pain and severe headache are two of the most common sources of pain that interfere with an individual's ability to enjoy social activities and negatively affect quality of life (1).

In the National Health Interview Survey, adults 18 years of age and over were asked a series of questions about whether they have had four types of pain during the 3 months prior to interview (low back, migraine/severe headache, neck, and facial ache in the jaw or joint in front of the ear). Respondents were instructed to report pain that lasted a whole day or more and not to include minor aches or pains. Respondents could report more than one type of pain and were included in each reported category. Trends in the percentage of Americans reporting each of these types of pain have been stable in recent years (Table 56).

Low back pain was the most commonly reported of the four types of pain overall and in each age group (Figure 30). In 2004, more than one-quarter of adults reported low back pain in the past 3 months (data table for Figure 30). Low back pain was most commonly reported among adults 45 years of age and over.

Figure 30 Adults reporting low back pain, migraine, neck, and face pain in the 3 months prior to interview, by age: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig30.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig30.ppt)

NOTES: Respondents were asked to report pain that lasted a whole day or more. Respondents reporting more than one type of pain were included in each category. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

In 2004, 15% of adults reported migraine/severe headache and 15% also reported neck pain. Adults 18–44 years of age reported migraine/severe headache pain almost three times as frequently as adults 65 years and over. Migraine/severe headache is particularly prevalent among women in their reproductive years (Table 56). In contrast to the pattern for migraine/severe headache, prevalence of neck pain varied less by age and was higher among adults 45–64 years of age than among those in other age groups.

Facial ache or pain in the joint in front of the ear was reported by 4% of adults in 2004. It was more common among younger and middle-age adults than among older adults 65 years of age and over.

#### Reference

1 National Institute of Neurological Disorders and Stroke. Low back pain fact sheet. Available from: www.ninds.nih.gov/health_and_medical/pubs/back_pain.htm.

### Low Back Pain

Women of all ages, race and ethnicity groups, and income levels report low back pain more often than men.

Low back pain is the second most common neurological ailment in the United States—only headache (when all types and severity levels are considered) is more common (1). Obesity, smoking, weight gain during pregnancy, stress, poor physical condition, posture inappropriate for the activity being performed, and poor sleeping position can contribute to low back pain. Low back pain places considerable stress on the health care system in terms of visits and procedures for diagnosis, treatment, and medication management. In addition, there are substantial indirect costs associated with reduced productivity. Low back pain is the most common cause of job-related disability and a leading contributor to missed work, and reduced productivity at work (1,2).

In the National Health Interview Survey, the presence of pain is measured by asking adult respondents 18 years of age and over about low back pain and other selected types of pain during the 3 months prior to interview. Respondents were instructed to report low back pain that lasted a whole day or more and not to include minor aches or pains. Trends in the percentage of adults reporting low back pain have remained stable in recent years (Table 56).

Women reported low back pain more often than men (29% compared with 25%) (data table for Figure 31). Gender differences persist within age, race and ethnicity (except among Asian adults), and income subgroups (Figure 31). Older women reported low back pain more often than older men (33% compared with 27%). Non-Hispanic black women reported low back pain about 30% more often, and Hispanic women reported it 40% more often than their male counterparts. Non-Hispanic white women and men had a higher prevalence of low back pain than other race and Hispanic origin groups, and they had a smaller male/female difference in prevalence than other racial and ethnic groups. Women of each income level reported low back pain more often than men at the same income level. Poor women were more likely to report low back pain than higher income women. Conversely, about one-quarter of men at all income levels reported low back pain.

Figure 31 Adults 18 years of age and over reporting low back pain in the 3 months prior to interview, by selected characteristics: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig31.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig31.ppt)

NOTES: Asian race includes persons of Hispanic and non-Hispanic origin. Persons of Hispanic origin may be of any race. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See data table for data points graphed and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### References

1 National Institute of Neurological Disorders and Stroke. Low back pain fact sheet. Available from: www.ninds.nih.gov/health_and_medical/pubs/back_pain.htm.
2 Hemp P. (2004). Presenteeism: at work—but out of it. Harv Bus Rev.

### Joint Pain

Severe joint pain is more common among adults age 65 years and over, low-income adults, and non-Hispanic black adults than among adults in other age, income, and racial and ethnic groups.

Osteoarthritis is the most common joint disorder and is characterized by joint pain, stiffness, and swelling. Joint pain can also be caused by injury, prolonged abnormal posture, or repetitious movements (1,2). In 2003, almost one-third of adults age 18 years and over and one-half of adults age 65 years and over reported joint pain, aching, or stiffness (excluding the back or neck) during the 30 days prior to interview (Table 57). The knee was the site of joint pain most commonly reported, followed by the shoulder, fingers, and hips. Trends in the prevalence of joint pain have remained stable in recent years.

In the 2003 National Health Interview Survey only, respondents who reported any joint pain, aching, or stiffness in or around a joint during the past 30 days were asked a follow-up question "During the past 30 days, how bad was your joint pain on average? Please answer on a scale of 0 to 10 where 0 is no pain or aching and 10 is pain or aching as bad as it can be." In this analysis, a reported score of 7–10 was classified as severe pain and 0–6 as lesser pain.

Severe joint pain increased with age (Figure 32). Women were more likely to report severe joint pain than men (10% compared with 7%). Although non-Hispanic black adults reported overall joint pain less often than non-Hispanic white adults, they were more likely to report severe joint pain. Asian adults had a lower percentage of severe joint pain than adults in other racial and ethnic groups. Persons with family income below 200% of the poverty line were nearly twice as likely to report severe joint pain as adults with family income of 200% or more of poverty (12%–13% compared with 7%).

Figure 32 Adults 18 years of age and over reporting joint pain in the 30 days prior to interview, by severity level and selected characteristics: United States, 2003

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig32.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig32.ppt)

NOTES: Adults who reported joint pain, aching, or stiffness during the past 30 days were asked to report on average the severity of the pain on a scale of 010 where 0 is no pain and 10 is pain or aching as bad as it can be. In this analysis, lesser pain is defined as 06 and severe pain as a response of 710. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

#### References

1 Medline Plus, National Library of Medicine: Osteoarthritis. Available from: www.nlm.nih.gov/medlineplus/ency/article/000423.htm.
2 Latko WA, Armstrong TJ, Franzblau A, et al. (1999). Cross-sectional study of the relationship between repetitive work and the prevalence of upper limb musculoskeletal disorders. Am J Ind Med.

### Narcotic Analgesic Drug Visits in Emergency Departments

In one-half of emergency department visits with severe pain recorded, a narcotic analgesic drug was prescribed or received.

The presence of pain can be discerned directly by asking people about the presence, type, location, and duration of specific types of pain (Figures 28–32). In addition, pain can be examined by investigating health care utilization involving pain treatments, such as emergency department (ED) visits during which narcotic analgesic drugs were prescribed. Narcotic analgesic drugs are used primarily to treat severe pain (Appendix II, Table XII). Physicians' decisions to prescribe narcotic analgesics are highly variable (1). Some studies conclude that narcotic analgesic drugs are underused in EDs, particularly among children, older adults, and minority populations (2).

In 2003–2004, 23% of all ED visits had a narcotic analgesic drug prescribed or provided during the visit (data table for Figure 33). In the National Hospital Ambulatory Medical Care Survey Emergency Room Component, presenting level of pain is abstracted from ED records. The presenting level of pain is recorded as none, mild, moderate, severe, or unknown or missing. About 16% of all ED visits in 2003–2004 had a recorded presenting pain level of no pain, 16% mild pain, 21% moderate pain, 14% severe pain, and 33% were unknown or missing on pain level (3). Children under 11 years of age were more likely to have an unknown or missing presenting pain level, but no difference in the percentage of unknown or missing pain level was noted by gender or by race.

Figure 33 Narcotic analgesic drug visits to the emergency department among visits with a severe pain level recorded, by age, sex, and race: United States, 2003–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig33.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig33.ppt)

NOTES: Narcotic drug visits are hospital emergency department visits with narcotic drugs prescribed or provided during the visit. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Ambulatory Medical Care Survey, Emergency Department Component.

Among ED visits with severe pain recorded, 50% had narcotic analgesic drugs prescribed or provided during the visit (data table for Figure 33). Males and females had similar rates of narcotic drugs for severe pain during ED visits (Figure 33). Children under age 18 were less likely than adults to receive a narcotic drug in the ED, regardless of presenting level of pain. Adults 65 years of age and over with severe pain were less likely to receive a narcotic drug than other adults with severe pain. Black people were less likely than white people to receive narcotic drugs for severe pain in the ED (40% compared with 53%).

#### References

1 Tamayo-Sarver JH, Dawson NV, Cydulka RK, Wigton RS, Baker DW. (2004). Variability in emergency physician decisionmaking about prescribing opioid analgesics. Ann Emerg Med.
2 Rupp T, Delaney KA. Inadequate analgesia in emergency medicine. Ann Emerg Med. 2004 Apr;43(4):494–503.
3 Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Ambulatory Medical Care Survey, unpublished analysis.

### Prescription Narcotic Drug Use

The use of narcotic drugs among women has increased from 1988–1994 to 1999–2002, largely due to increased use among non-Hispanic white women and women age 45 years and over.

In recent decades, the medical community has increasingly recognized the importance of treating and controlling pain (1). The goal of pain management is to return patients to a pain level that allows them to function better in their daily lives. Pain may be managed by nonpharmacologic and pharmacologic means. Nonpharmacologic treatments include biofeedback, relaxation techniques, massage, and heat or cold application. These approaches usually supplement pharmacologic treatment (2). Pharmacologic approaches include a variety of medication options. Minor pain may be controlled by non-narcotic medications such as aspirin, acetaminophen, or ibuprofen. More severe pain may require the use of narcotic medications, such as codeine and oxycodone.

The National Health and Nutrition Examination Survey (NHANES) collects data on the prescription drug use of survey participants living in the community through in-person household interviews. Prescription drug use is determined by examining the prescription labels of the participant's medications.

Between 1988–1994 and 1999–2002, the age-adjusted percentage of women reporting narcotic drug use in the month prior to interview increased by almost one-half from 3.6% to 5.3%. This increase was driven largely by an increase in narcotic drug use among women age 45 years and over (Figure 34). During this period, use of narcotic drugs rose by almost 75% among women 45–64 years of age to 5.7% and by more than 50% among women 65 years and over to 6.8%. This increased use has been primarily among non-Hispanic white women (data table for Figure 34). In contrast, reported narcotic drug use among adult men remained stable from 1988–1994 to 1999–2002 and there were no significant differences in use for men by race or ethnicity.

Figure 34 Adults 18 years of age and over reporting narcotic drug use in the month prior to interview, by sex and age: United States, 1988–1994 and 1999–2002

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig34.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig34.ppt)

NOTES: *19992002 data have a relative standard error of 20%30%. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

In 1999–2002, women of all ages reported more narcotic drug use than men (Figure 34). Non-Hispanic white women were almost twice as likely to report narcotic use as women of Mexican origin (5.9% compared with 3.2%).

#### References

1 Phillips DM. (2000). JCAHO pain management standards are unveiled. JAMA.
2 National Pharmaceutical Council, Inc. and Joint Commission on Accreditation of Healthcare Organizations. Pain: Current understanding of assessment, management, and treatments. Reston, VA: NPC; 2001.

### Knee and Nonfracture Hip Replacements

Rates of hospitalizations to replace painful hips and knees have substantially increased since 1992–1993.

Knee and hip replacement are two types of surgical procedures for treating significant pain, loss of joint function, and impaired mobility most commonly associated with osteoarthritis (1). Painful knees and hips are common symptoms among older adults, with about 30% of adults 65 years of age and over reporting knee pain or stiffness in the past 30 days and 15% reporting hip pain or stiffness (Table 57). In 2003, knee replacement surgery was estimated to cost the Nation $11.9 billion and hip replacement $12.2 billion (2). Aging of the American population and increasing trends in overweight and obesity may further increase the prevalence of joint problems in the future.

Data from the National Hospital Discharge Survey provide information on trends in knee and hip replacement surgery. In addition to pain, hip replacement surgery is also performed to treat a fractured hip, often on an emergency basis. Because the focus of this Special Feature is on pain and its consequences, the analysis of hip replacement surgery excludes hip replacement surgery with a hip fracture diagnosis. Osteoarthritis is the most common diagnosis associated with knee and nonfracture hip replacement procedures—97% of knee replacements and almost 70% of nonfracture hip replacements in 2003–2004 were for patients with a diagnosis of osteoarthritis (3).

In 2003–2004 among adults 18 years of age and over, the knee replacement rate was 52% higher than the nonfracture hip replacement rate. There were, on average, approximately 428,000 hospital discharges per year with any mention of a knee replacement and 282,000 hospital discharges with any mention of nonfracture hip replacement (data table for Figure 35).

Figure 35 Hospital discharges for knee and nonfracture hip replacement surgery among adults 45 years of age and over, by sex and age: United States, 1992–1993 and 2003–2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig35.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig35.ppt)

NOTES: Up to four inpatient hospital procedures were coded for each stay. Hip replacement excludes procedures for hip fracture. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Discharge Survey.

Between 1992–1993 and 2003–2004, knee replacement discharge rates increased among both men and women 45 years of age and over (Figure 35). Knee replacement discharges were more common among adults 65 years of age and over than among those age 45–64 years. During this time period, rates nearly tripled among adults 45–64 years of age and nearly doubled among adults 65 years and over. In both 1992–1993 and 2003–2004, hospital discharges with knee replacement surgery were more common among women than men.

Between 1992–1993 and 2003–2004, nonfracture hip replacement discharge rates increased among men and women 45 years of age and over (Figure 35). In 2003–2004, the nonfracture hip replacement discharge rate was more than twice as great among older adults 65 years and over than adults 45–64 years. Between 1992–1993 and 2003–2004, rates in the 45–64 year age group more than doubled and rates among older adults increased by 70% among men and 50% among women. In contrast to knee replacement, nonfracture hip replacement discharges were equally likely among men and women.

#### References

1 National Institutes of Health. NIH Consensus Development Conference on Total Knee Replacement. 2003. Available from: consensus.nih.gov/2003/2003TotalKneeReplacement117html.htm.
2 Agency for Healthcare Research and Quality. HCUP Nationwide Inpatient Sample (NIS). Available from: www.hcup-us.ahrq.gov/.
3 Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Discharge Survey, unpublished analysis.

### Ambulatory Medical Care Expenses Associated with Headaches

Ambulatory medical care expenses for adults suffering from headaches and who sought ambulatory medical care or purchased prescribed medications averaged about $570 per person per year in 2002–2003.

Recent statistics on headaches suggest that only a small proportion of adults who experience headaches receive professional medical treatment for their condition, indicating that many people manage their pain themselves using painkillers purchased over the counter, or other self-care. In 2003, 15% of adults reported a migraine or severe headache in the 3 months prior to interview (Table 56). However, data from the Medical Expenditure Panel Surveys for 2002 and 2003 indicate only 3.5% of adults had ambulatory visits and/or prescribed drug purchases for treatment of headaches over a one-year period (1). Ambulatory medical care includes care obtained in doctors' offices, hospital outpatient clinics, and emergency rooms, as well as prescribed medicines purchased during the survey year. Ambulatory medical care expenses for headaches averaged about $570 per person with such expenses, although expenses of individuals varied substantially. The median ambulatory medical care headache expense per person with any such expense reported was $212 in 2002–2003.

The percentage of adults who received ambulatory medical care for headaches varied by age and sex (Figure 36). Women were more likely to obtain care than men, reflecting their higher prevalence of headaches. Adults age 45–64 years were most likely to have ambulatory medical care expenses for headaches and those age 65 years or over were least likely to have these expenses.

Figure 36 Adults reporting ambulatory medical care use for headaches and associated ambulatory medical care expenses, by age and sex: United States, 2002–2003

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig36.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig36.ppt)

NOTES: Estimates are for adults age 18 and over who had ambulatory medical care (office-based, hospital outpatient, and emergency room settings) and/or prescribed medicine expenses for headaches. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Agency for Heathcare Research and Quality, Center for Financing, Access, and Cost Trends, Household Component, Medical Expenditure Panel Survey.

Average ambulatory medical care expenses for headaches ($566) per adult with such expenses varied little by age and sex (Figure 36). Ambulatory care expenses for headache accounted for 15% of total ambulatory expenses for these adults (1). This percentage decreased with age from 18% among adults age 18–44 years to 10.5% among those 65 years or over. The smaller share of ambulatory care expenses for headaches among adults 65 years and over compared with younger adults resulted in large part from increasing expenses for other medical conditions among older adults.

#### Reference

1 Machlin SR, Miller GE. Health service use and expenses for migraines and other headaches, 2002–03 (average annual estimates). Statistical Brief #115. February 2006. Agency for Healthcare Research and Quality, Rockville, MD. Available from: www.meps.ahrq.gov/mepsweb/data_files/publications/st115/stat115.pdf.

### Health Status Measures among Adults with and without Low Back Pain

People with recent low back pain have worse overall health status as measured by activity limitation, respondent-assessed health status, and serious psychological distress than people without recent low back pain.

Pain interferes with an individual's ability to work and engage in many social activities. It may be directly related to health status measures such as activity limitation—for example, people with low back pain may be unable to function in some jobs or to work at all. Moreover, even intermittent pain may affect people's assessments of their physical and mental health. Pain does not necessarily cause serious psychological distress, limitation of activity, or poor health status, but may interact with physical and mental health status to affect perceptions of pain, care-seeking behaviors, speed of recovery, and ability to function.

In the National Health Interview Survey, adult respondents were asked about low back pain in the 3 months prior to interview. Respondents were instructed to report low back pain that lasted a whole day or more and not to include minor aches or pains. Additional questions included respondent-assessed health status, activity limitation due to chronic health conditions, and a series of questions designed to assess serious psychological distress (See Appendix II, Health status, respondent-assessed; Limitation of activity; Serious psychological distress).

In 2004, adults who reported low back pain lasting more than 24 hours during the past 3 months reported worse health status, using a number of different measures, than people who did not report recent low back pain, regardless of age (Figure 37). Overall, 28% of adults with low back pain said they had a limitation of activity caused by a chronic condition, compared with 10% of adults who did not report low back pain. Adults with recent low back pain were about three times as likely to report fair or poor health status and more than four times as likely to experience serious psychological distress as people without low back pain.

Figure 37 Health status measures among adults 18 years of age and over with and without low back pain, by age: United States, 2004

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig37.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig37.ppt)

NOTES: Respondents were asked to report low back pain that lasted a whole day or more. See data table for data points graphed, standard errors, and additional notes.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Within each age group, adults with low back pain reported worse health status than those without low back pain. For example, among adults 65 years and over more than one-half who reported recent low back pain had a limitation in their usual activity compared with 27% without recent low back pain, and 40% with recent low back pain rated their health as fair or poor, compared with 19% of older people who did not report recent low back pain.

## Technical Notes

### Data Sources and Comparability

Data for The Chartbook on Trends in the Health of Americans come from many different surveys and data systems and cover a broad range of years. Detailed descriptions of data sources are contained in Appendix I.

### Data Presentation

Many measures in The Chartbook on Trends in the Health of Americans are shown for people in specific age groups because of the strong effect age has on most health outcomes. Some estimates are age adjusted using the age distribution of the 2000 standard population, and this is noted in the data tables that accompany each figure (see Appendix II, Age adjustment). For some figures, data years are combined to increase sample size and reliability of the estimates. Time trends for some measures are not presented because of the relatively short amount of time that comparable national estimates are available.

#### Graphic Presentation

Most line charts, for which only selected years of data are displayed, have dot markers on the data years. Line charts for which data are displayed for every year in the trend are shown without the use of dot markers. Figures 24 and 27 do not show dot markers, although selected years of data are graphed for years prior to 1997 and 1995 respectively. Most trends are shown on a linear scale to emphasize absolute differences over time. The linear scale is the scale most frequently used and recognized, and it emphasizes the absolute changes between data points over time (1). The time trend for overall mortality measures is shown on a logarithmic (or log) scale to emphasize the rate of change and to enable measures with large differences in magnitude to be shown on the same chart. Log scales emphasize the relative or percentage change between data points. Readers are cautioned that one potential disadvantage to log scale is that the absolute magnitude of changes may appear smaller than the untransformed statistics would indicate (2). When interpreting data on a log scale, the following points should be kept in mind:

1. A sloping straight line indicates a constant rate (not amount) of increase or decrease in the values,
2. A horizontal line indicates no change,
3. The slope of the line indicates the rate of increase or decrease,
4. Parallel lines, regardless of their magnitude, depict similar rates of change (1).

#### Tabular Presentation

Following the Technical Notes are data tables that present the data points graphed in each figure. Some data tables contain additional data that were not graphed because of space considerations. Standard errors for data points are provided for many measures. Additional information clarifying and qualifying the data are included in table notes and Appendix I and II references.

### Special Feature: Pain

Data on pain prevalence, location, and characteristics presented in the Special Feature on Pain come from a variety of data sources, including the National Health and Nutrition Examination Survey (NHANES), the National Health Interview Survey (NHIS), the National Hospital Ambulatory Medical Care Survey (NHAMCS) Emergency Department Component, the National Hospital Discharge Survey (NHDS), and the Medical Expenditure Panel Survey (MEPS). Data on pain prevalence is self-reported using a survey questionnaire in the NHANES and the NHIS. The NHANES also contains data on prescription drug use in the past month, which is collected from the participant by viewing medication containers (when available). Data from the NHDS and NHAMCS are abstracted from medical records. Exact wording of the questions, including reference periods for which the pain occurred, vary by survey. Detailed descriptions of these data sources are contained in Appendix I and information about the specific questions used in the Special Feature are below.

#### National Health and Nutrition Examination Survey (NHANES)

##### NHANES self-reported questions on pain

The 1999–2002 NHANES contained a series of questions for respondents concerning pain they experienced during the past month. Figures 28 and 29 use data based on the following questions:

"DURING THE PAST MONTH, (have you/has sampled adult) had a problem with pain that lasted more than 24 hours?"

For people who responded "yes" to this question, a follow-up question was asked:

"For how long (have you/has sample adult) experienced this pain? Would you say . . .

1 = Less than a month,

2 = At least 1 month but less than 3 months,

3 = At least 3 months but less than 1 year, or

4 = Greater than 1 year?

7 = Refused

9 = Don't know"

##### NHANES prescription drug data

The questionnaire administered to all participants also included a question on whether they had taken a prescription drug in the past month. Those who answered "yes" were asked to show the interviewer the medication containers for all the prescriptions. For each drug reported, the interviewer entered the product's complete name from the container. If no container was available, the interviewer asked the participant to verbally report the name of the drug. Additionally, participants were asked how long they had been taking the drug and the main reason for use. All reported medication names were converted to their standard generic ingredient name. For multi-ingredient products, the ingredients were listed in alphabetical order (i.e., Tylenol #3 would be listed as Acetaminophen; Codeine). No trade or proprietary names were provided on the data file. More information on prescription drug data collection and coding in the NHANES is available from: www.cdc.gov/nchs/data/nhanes/frequency/rxq_rxdoc.pdf. More information on NHANES III prescription drug data collection and coding is available from: www.cdc.gov/nchs/data/nhanes/nhanes3/PUPREMED-acc.pdf. Also see Appendix I, National Health and Nutrition Examination Survey.

#### National Health Interview Survey (NHIS)

##### NHIS self-reported questions on pain

Sample adults and knowledgable proxy respondents (1% of sample adult respondents) were asked a series of questions about pain. The recall period varies by the type of pain mentioned. For back pain, severe headache or migraine, neck pain, and face pain, respondents were asked about pain that occurred at any time in the past 3 months. Respondents were also asked about joint pain they experienced in the past 30 days. The exact questions used were:

"The following questions are about pain you may have experienced in the PAST 3 MONTHS. Please refer to pain that LASTED A WHOLE DAY OR MORE. Do not report aches and pains that are fleeting or minor.

DURING THE PAST 3 MONTHS, did [you/sample adult] have severe headaches or migraines?"

This identical question was asked for several types of pain, substituting the following types of pain for "severe headaches or migraines": neck pain; low back pain; and facial ache or pain in the jaw muscles or the joint in front of the ear.

Additionally, respondents were also asked:

"DURING THE PAST 30 DAYS, have you had any symptoms of pain, aching, or stiffness in or around a joint?"

In 2003 only, respondents who reported joint symptoms were asked a follow-up question:

"DURING THE PAST 30 DAYS, how bad was your joint pain on average?" Respondents were instructed to answer on a scale of 0–10 where 0 is no pain or aching and 10 is pain or aching as bad as it can be. In the Figure 32 analysis, lesser joint pain was defined as 0–6 and severe pain was defined as a response of 7–10. This analysis excludes a small number of adults who did not provide information on both joint pain questions.

#### National Hospital Ambulatory Medical Care Survey (NHAMCS) Emergency Department Component

For each hospital emergency department (ED) visit sampled in the NHAMCS, the presenting level of pain as recorded on the medical record is abstracted to the patient record form, using the following categories: Unknown, None, Mild, Moderate, and Severe. In 2003–2004, presenting level of pain was unknown or missing in 33% of ED visits. This could be due to unconsciousness, poor communication with the patient (or young child), or failure to record the pain level on the medical record for some other reason. Narcotic drugs were prescribed or provided in 16% of ED visits with unknown or missing pain level (see data table for Figure 33).

##### NHAMCS drug data

Data collection in the NHAMCS-ED component is from the medical record rather than from individuals. Medications that were prescribed or provided during the ED visit are recorded on the patient record form. Generic as well as brand name drugs are included, as are nonprescription and prescription drugs. Up to eight medications per visit could be listed in 2003–2004.

For more information on drugs collected by the NAMCS/ NHAMCS, see the Ambulatory Care Drug Database, available from: www2.cdc.gov/drugs/, or ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Dataset_Documentation/NAMCS/doc01.pdf, or ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Dataset_Documentation/NHAMCS/doc01.pdf. Also see Appendix I, National Ambulatory Care Medical Survey and National Hospital Ambulatory Medical Care Survey, and Appendix II, Drugs; National Drug Code Directory (NDC).

#### National Hospital Discharge Survey (NHDS)

The National Hospital Discharge Survey collects data on hospital stays in non-federal short-stay hospitals in the United States, including diagnoses, procedures performed, age, sex, and race. Up to four procedures are coded for each hospital stay. Procedure codes are based on the International Classification of Diseases, Ninth Revision, Clinical Modification (ICD–9–CM). In Figure 35, ICD–9–CM codes used for knee replacement are 81.54 and for hip replacement 81.51–52, excluding hip fracture codes 820 and 733.14). In 2003–2004, 28% of hip replacements were for hip fracture. Data in Figure 35 show any-listed procedures; if more than one procedure with the same ICD code (e.g., hip replacement) is performed during the hospitalization it is counted only once.

#### Medical Expenditure Panel Survey (MEPS)

The Medical Expenditure Panel Survey produces nationally representative estimates of health care use, expenditures, source of payment, and insurance coverage for the United States civilian noninstitutionalized population. For each medical care visit or prescription drug during a 1-year period, the respondent reports the condition for which the visit was made, which is then coded using the ICD–9–CM system. Expenses associated with each visit or prescription drug are recorded. In Figure 36, headache is classified using ICD–9–CM codes 346, 784.0, and 307.81. See Appendix I: Medical Expenditure Panel Survey.

### References

1 Page RM, Cole GE, Timmreck TC. Basic epidemiological methods and biostatistics: A practical guidebook. Sudbury, MA: Jones and Bartlett Publishers, 1995.
2 Jekel JF, Elmore JG, Katz DL. Epidemiology biostatistics and preventive medicine. Philadelphia, PA: W.B. Saunders Company, 1996.

## List of Chartbook Figures

Population (figures 1-5) Total population Population by age group Population by race Poverty rates Low income

Health Insurance and Expenditures (figures 6-9) Health Insurance coverage Uninsured by selected characteristics National health expenditures as a percent of GDP Personal health expenditures

Health Risk Factors (figures 10-14) Cigarette smoking Binge drinking and marijuana use Physical activity, adults Overweight and obesity Untreated dental caries

Morbidity and Limitation of Activity (figures 15-18) Three or more chronic conditions Chronic health conditions, children Chronic health conditions, adults Chronic health conditions, older adults

Health Care Utilization (figures 19-23) Dental visits Influenza vaccination Emergency department visits for falls Visits to physician offices and hospital outpatient departments Gastric bypass and other bariatric procedures

Mortality (figures 24-27) Life expectancy Infant, neonatal, and postneonatal mortality rates Infant mortality rates by race Leading causes of death

Special Feature: Pain (figures 28-37) Pain Pain duration Low back pain, migraine, neck, and face pain Low back pain Joint pain Narcotic analgesic drug visits to the emergency department Narcotic drug use Hospital discharges Ambulatory medical care Health status measures

## Data Tables for Figures 1–37

Data table for Figure 1. Total population and older population: United States, 1950–2050 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig01.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig01.ppt)

NOTE: See Chartbook Figure 1.

Year | All ages | 65 years and over | 65–74 years | 75 years and over
| Number
1950 | 150,697,361 | 12,194,612 | 8,339,960 | 3,854,652
1960 | 179,323,175 | 16,559,580 | 10,996,842 | 5,562,738
1970 | 203,211,926 | 20,065,502 | 12,435,456 | 7,630,046
1980 | 226,545,805 | 25,549,427 | 15,580,605 | 9,968,822
1990 | 248,709,873 | 31,078,895 | 18,045,495 | 13,033,400
2000 | 281,421,906 | 34,991,753 | 18,390,986 | 16,600,767
2004 | 293,655,404 | 36,293,985 | 18,463,472 | 17,830,513
2005 | 296,496,649 | 36,681,501 | 18,615,309 | 18,066,192
2010 | 308,935,581 | 40,243,713 | 21,269,509 | 18,974,204
2020 | 335,804,546 | 54,631,891 | 31,779,159 | 22,852,732
2030 | 363,584,435 | 71,453,471 | 37,947,933 | 33,505,538
2040 | 391,945,658 | 80,049,634 | 35,469,908 | 44,579,726
2050 | 419,853,587 | 86,705,637 | 37,942,437 | 48,763,200
| Percent
1950 | 100.0 | 8.1 | 5.5 | 2.6
1960 | 100.0 | 9.2 | 6.1 | 3.1
1970 | 100.0 | 9.9 | 6.1 | 3.8
1980 | 100.0 | 11.3 | 6.9 | 4.4
1990 | 100.0 | 12.5 | 7.3 | 5.2
2000 | 100.0 | 12.4 | 6.5 | 5.9
2004 | 100.0 | 12.4 | 6.3 | 6.1
2005 | 100.0 | 12.4 | 6.3 | 6.1
2010 | 100.0 | 13.0 | 6.9 | 6.1
2020 | 100.0 | 16.3 | 9.5 | 6.8
2030 | 100.0 | 19.7 | 10.4 | 9.2
2040 | 100.0 | 20.4 | 9.0 | 11.4
2050 | 100.0 | 20.7 | 9.0 | 11.6

NOTES: Data are for the resident population. Data for 1950 exclude Alaska and Hawaii. Data for 2010–2050 are projected. See Appendix II, Population.

SOURCES: U.S. Census Bureau: 1950 Nonwhite population by race. Special Report P-E, No.3B. Washington, DC. U.S. Government Printing Office, 1951 [data for 1950]; U.S. Census of Population: 1960, Number of inhabitants, PC(1)-A1, United States Summary, 1964 [data for 1960]; Number of inhabitants, final report PC(1)-A1, United States Summary, 1971 [data for 1970]; U.S. Census Bureau, 1980 Census of Population, General population characteristics, United States Summary (PC80–1-B1) [data for 1980]; 1990 Census of Population, General population characteristics, United States Summary (CP-1-1) [data for 1990]; Table 1. Annual estimates of the population by sex and five-year age groups for the United States: April 1, 2000 to July 1, 2004 (NC-EST2004-01) available from: www.census.gov/popest/national/asrh/NC-EST2004/NC-EST2004-01.xls [data for Census 2000]; U.S. Census Bureau: Monthly postcensal resident populations, from April 1, 2000 to July 1, 2005 by age, sex, race, and Hispanic origin available from: www.census.gov/popest/national/asrh/2004_nat_res.html [data for 2004 and 2005]; U.S. interim projections by age, sex, race, and Hispanic origin detail file. Available from: www.census.gov/ipc/www/usinterimproj/ [data for projections].

Data table for Figure 2. Population in group quarters, by type of setting: United States, 1990 and 2000 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig02.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig02.ppt)

NOTE: See Chartbook Figure 2.

| 1990 | | 2000
Population and setting | Number | Percent | Number | Percent
Total U.S. population | 248,709,870 | 100.00 | 281,421,910 | 100.00
Total in group quarters | 6,697,740 | 2.69 | 7,778,630 | 2.76
Institutionalized group quarters | 3,334,020 | 1.34 | 4,059,040 | 1.44
Correctional institutions | 1,115,110 | 0.45 | 1,976,020 | 0.70
Nursing homes | 1,772,030 | 0.71 | 1,720,500 | 0.61
Juvenile institutions | 104,200 | 0.04 | 128,280 | 0.05
Other institutions | 342,680 | 0.14 | 234,240 | 0.08
Noninstitutionalized group quarters | 3,363,730 | 1.35 | 3,719,590 | 1.32
College dormitories | 1,953,560 | 0.79 | 2,064,130 | 0.73
Military quarters | 589,700 | 0.24 | 355,160 | 0.13
Group homes | 211,680 | 0.09 | 454,060 | 0.16
Emergency and transitional shelters | 178,640 | 0.07 | 170,710 | 0.06
Other noninstitutional group quarters | 430,160 | 0.17 | 675,550 | 0.24

NOTES: Numbers are rounded to the nearest 10. Other institutions include hospitals or wards, hospices, and schools for the handicapped. Other noninstitutional group quarters include shelters for abused women, soup kitchens, crews of maritime vessels, agriculture workers' dormitories, and religious group quarters. See Appendix II, Group quarters; Population.

SOURCE: U.S. Census Bureau, Census 2000 Summary File 1, Matrix PCT16; 1990 Summary tape file 1 (STF 1)-100-Percent data.

Data table for Figure 3. Population in selected race and Hispanic origin groups, by age: United States, 1980–2005 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig03.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig03.ppt)

NOTE: See Chartbook Figure 3.

| All ages | | | | Under 18 years | | | | 18 years and over
Race and Hispanic origin | 1980 | 1990 | 2000 | 2005 | 1980 | 1990 | 2000 | 2005 | 1980 | 1990 | 2000 | 2005
Total | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0
Hispanic or Latino | 6.4 | 9.0 | 12.5 | 14.4 | 8.8 | 12.2 | 17.1 | 19.7 | 5.5 | 7.9 | 11.0 | 12.7
Not Hispanic or Latino:
White | 79.9 | 75.7 | 69.5 | 66.9 | 74.2 | 68.9 | 61.3 | 58.3 | 82.1 | 78.1 | 72.3 | 69.7
Black or African American | 11.5 | 11.8 | 12.2 | 12.3 | 14.5 | 14.7 | 14.9 | 14.7 | 10.4 | 10.7 | 11.3 | 11.4
American Indian or Alaska Native | 0.6 | 0.7 | 0.7 | 0.8 | 0.8 | 1.0 | 1.0 | 0.9 | 0.5 | 0.6 | 0.7 | 0.7
Asian | 1.6 | 2.8 | 3.7 | 4.2 | 1.7 | 3.1 | 3.5 | 3.8 | 1.5 | 2.7 | 3.8 | 4.3
Native Hawaiian or Other Pacific Islander | . . . | . . . | 0.1 | 0.1 | . . . | . . . | 0.2 | 0.2 | . . . | . . . | 0.1 | 0.1
2 or more races | . . . | . . . | 1.2 | 1.3 | . . . | . . . | 2.2 | 2.4 | . . . | . . . | 0.9 | 1.0

. . . Category not applicable.

NOTES: Data are for the resident population. Persons of Hispanic origin may be of any race. Race data for 2000 and beyond are not directly comparable with data for 1980 and 1990. Individuals could report only one race in 1980 and 1990, and more than one race beginning in 2000. Persons who selected only one race in 2000 and beyond are shown in single-race categories; persons who selected more than one race in 2000 and beyond are shown as having 2 or more races and are not included in the single-race categories. In 1980 and 1990, the Asian category included Asian and Native Hawaiian or Other Pacific Islander; in 2000 and beyond this category includes only Asian. See Appendix II, Hispanic origin; Race.

SOURCES: U.S. Census Bureau: U.S. population estimates, by age, sex, race, and Hispanic origin: 1980 to 1991. Current population reports, series P-25, no 1095. Washington, DC. U.S. Government Printing Office, February 1993 [data for April 1, 1980 and April 1, 1990]; U.S. Census Bureau: Monthly postcensal resident populations, from July 1, 2000 to July 1, 2004 by age, sex, race, and Hispanic origin, available from: www.census.gov/popest/national/asrh/2004_nat_res.html [data for April 1, 2000 and July 1, 2005].

Data table for Figure 4. Poverty by age: United States, 1966–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig04.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig04.ppt)

NOTE: See Chartbook Figure 4.

Year | All ages | Under 18 years | 18–64 years | 65 years and over
| Percent of persons with family income below the poverty level
1966 | 14.7 | 17.6 | 10.5 | 28.5
1967 | 14.2 | 16.6 | 10.0 | 29.5
1968 | 12.8 | 15.6 | 9.0 | 25.0
1969 | 12.1 | 14.0 | 8.7 | 25.3
1970 | 12.6 | 15.1 | 9.0 | 24.6
1971 | 12.5 | 15.3 | 9.3 | 21.6
1972 | 11.9 | 15.1 | 8.8 | 18.6
1973 | 11.1 | 14.4 | 8.3 | 16.3
1974 | 11.2 | 15.4 | 8.3 | 14.6
1975 | 12.3 | 17.1 | 9.2 | 15.3
1976 | 11.8 | 16.0 | 9.0 | 15.0
1977 | 11.6 | 16.2 | 8.8 | 14.1
1978 | 11.4 | 15.9 | 8.7 | 14.0
1979 | 11.7 | 16.4 | 8.9 | 15.2
1980 | 13.0 | 18.3 | 10.1 | 15.7
1981 | 14.0 | 20.0 | 11.1 | 15.3
1982 | 15.0 | 21.9 | 12.0 | 14.6
1983 | 15.2 | 22.3 | 12.4 | 13.8
1984 | 14.4 | 21.5 | 11.7 | 12.4
1985 | 14.0 | 20.7 | 11.3 | 12.6
1986 | 13.6 | 20.5 | 10.8 | 12.4
1987 | 13.4 | 20.3 | 10.6 | 12.5
1988 | 13.0 | 19.5 | 10.5 | 12.0
1989 | 12.8 | 19.6 | 10.2 | 11.4
1990 | 13.5 | 20.6 | 10.7 | 12.2
1991 | 14.2 | 21.8 | 11.4 | 12.4
1992 | 14.8 | 22.3 | 11.9 | 12.9
1993 | 15.1 | 22.7 | 12.4 | 12.2
1994 | 14.5 | 21.8 | 11.9 | 11.7
1995 | 13.8 | 20.8 | 11.4 | 10.5
1996 | 13.7 | 20.5 | 11.4 | 10.8
1997 | 13.3 | 19.9 | 10.9 | 10.5
1998 | 12.7 | 18.9 | 10.5 | 10.5
1999 | 11.9 | 17.1 | 10.1 | 9.7
2000 | 11.3 | 16.2 | 9.6 | 9.9
2001 | 11.7 | 16.3 | 10.1 | 10.1
2002 | 12.1 | 16.7 | 10.6 | 10.4
2003 | 12.5 | 17.6 | 10.8 | 10.2
2004 | 12.7 | 17.8 | 11.3 | 9.8

NOTES: Data are for the civilian noninstitutionalized population. Poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See Appendix II, Poverty. See related Table 3.

SOURCES: U.S. Census Bureau, Current Population Survey, March 1967–2005. U.S. Census Bureau. DeNavas-Walt C, Proctor B, Hill LC. Income, poverty, and health insurance coverage in the United States: 2004. Current population reports, series P-60, no 229. Washington, DC: U.S. Government Printing Office. 2005.

Data table for Figure 5. Low income by age, race, and Hispanic origin: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig05.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig05.ppt)

NOTE: See Chartbook Figure 5.

| Percent of poverty level
Characteristic | Below 100% | 100%–less than 200% | Below 100% | 100%–less than 200%
| Percent | | Number in millions
All ages
All races and origins | 12.7 | 18.5 | 37.0 | 53.8
Hispanic or Latino | 21.9 | 30.3 | 9.1 | 12.6
Black or African American only | 24.7 | 24.0 | 9.0 | 8.7
Asian only | 9.8 | 16.3 | 1.2 | 2.0
White only, not Hispanic or Latino | 8.6 | 15.1 | 16.9 | 29.4
Under 18 years
All races and origins | 17.8 | 21.4 | 13.0 | 15.7
Hispanic or Latino | 28.9 | 33.3 | 4.1 | 4.7
Black or African American only | 33.6 | 26.9 | 3.8 | 3.0
Asian only | 10.0 | 19.4 | 0.3 | 0.6
White only, not Hispanic or Latino | 10.5 | 16.2 | 4.5 | 7.0
18–64 years
All races and origins | 11.3 | 15.5 | 20.5 | 28.2
Hispanic or Latino | 18.3 | 28.3 | 4.6 | 7.2
Black or African American only | 20.3 | 21.1 | 4.5 | 4.7
Asian only | 9.3 | 14.0 | 0.8 | 1.2
White only, not Hispanic or Latino | 8.3 | 11.9 | 10.2 | 14.7
65 years and over
All races and origins | 9.8 | 28.1 | 3.5 | 9.9
Hispanic or Latino | 18.7 | 34.0 | 0.4 | 0.7
Black or African American only | 23.9 | 34.7 | 0.7 | 1.0
Asian only | 13.6 | 25.5 | 0.1 | 0.3
White only, not Hispanic or Latino | 7.5 | 27.1 | 2.2 | 7.8

NOTES: Data are for the civilian noninstitutionalized population. Persons of Hispanic origin may be of any race. Black and Asian races include persons of both Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See related Table 3. See Appendix II, Hispanic origin; Poverty; Race.

SOURCES: DeNavas-Walt C, Proctor B, Hill LC. Income, poverty, and health insurance coverage in the United States: 2004. Current population reports, series P-60 no 229. Washington, DC: U.S. Government Printing Office. 2005; Age and sex of all people, family members, and unrelated individuals iterated by income-to-poverty ratio and race: 2004, available from: pubdb3.census.gov/macro/032005/pov/new01_000.htm.

Data table for Figure 6. Health insurance coverage at the time of interview among persons under 65 years of age: United States, 1984–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig06.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig06.ppt)

NOTE: See Chartbook Figure 6.

| Health insurance coverage at the time of interview
| Private | | Medicaid | | Uninsured
Year | Percent | SE | Percent | SE | Percent | SE
1984 | 76.8 | 0.6 | 6.8 | 0.3 | 14.5 | 0.4
1989 | 75.9 | 0.4 | 7.2 | 0.2 | 15.6 | 0.3
1994 | 69.9 | 0.4 | 11.2 | 0.3 | 17.5 | 0.3
1995 | 71.3 | 0.4 | 11.5 | 0.2 | 16.1 | 0.2
1996 | 71.2 | 0.5 | 11.1 | 0.3 | 16.6 | 0.3
1997 | 70.7 | 0.4 | 9.7 | 0.2 | 17.5 | 0.2
1998 | 72.1 | 0.4 | 8.9 | 0.2 | 16.6 | 0.2
1999 | 72.8 | 0.3 | 9.1 | 0.2 | 16.1 | 0.2
2000 | 71.5 | 0.4 | 9.5 | 0.2 | 17.0 | 0.3
2001 | 71.2 | 0.4 | 10.4 | 0.2 | 16.4 | 0.3
2002 | 69.4 | 0.4 | 11.8 | 0.2 | 16.8 | 0.2
2003 | 68.9 | 0.4 | 12.3 | 0.2 | 16.5 | 0.3
2004 | 68.8 | 0.4 | 12.5 | 0.2 | 16.4 | 0.2

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Medicaid includes other public assistance through 1996; includes state-sponsored health plans starting in 1997; and includes State Children's Health Insurance Program (SCHIP) starting in 1999. Uninsured persons are not covered by private insurance, Medicaid, SCHIP, public assistance (through 1996), state-sponsored or other government-sponsored health plans (starting in 1997), Medicare, or military plans. Persons with Indian Health Service only are considered uninsured. Percents do not add to 100 because the percentage of persons with Medicare, military plans, and other government-sponsored plans is not shown and because persons with both private insurance and Medicaid appear in both categories. Starting with third-quarter 2004 data, persons under 65 years of age with no reported coverage were asked explicitly about Medicaid coverage. Estimates for Medicaid coverage shown in this table include the additional information. See Appendix II, Health insurance coverage. See related Tables 133–135.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 7. Health insurance status prior to interview among persons under 65 years of age, by selected characteristics: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig07.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig07.ppt)

NOTE: See Chartbook Figure 7.

| Length of time uninsured prior to interview
| Total uninsured prior to interview | | More than 12 months | | Any period up to 12 months
Characteristic | Percent | SE | Percent | SE | Percent | SE
Age
Under 65 years | 20.1 | 0.3 | 11.4 | 0.2 | 7.6 | 0.2
Under 18 years | 12.5 | 0.3 | 5.4 | 0.2 | 6.3 | 0.2
18–24 years | 36.1 | 0.7 | 19.9 | 0.6 | 14.8 | 0.5
25–34 years | 31.1 | 0.6 | 18.1 | 0.4 | 11.7 | 0.4
35–44 years | 20.9 | 0.4 | 13.0 | 0.4 | 6.7 | 0.2
45–54 years | 16.2 | 0.4 | 10.1 | 0.3 | 5.0 | 0.2
55–64 years | 13.4 | 0.4 | 8.7 | 0.3 | 3.7 | 0.2
Percent of poverty level
Below 100% | 35.8 | 0.7 | 23.2 | 0.7 | 11.4 | 0.5
100%–less than 150% | 36.3 | 0.8 | 23.2 | 0.8 | 11.8 | 0.6
150%–less than 200% | 32.7 | 1.1 | 19.9 | 0.9 | 11.7 | 0.6
200% or more | 13.1 | 0.3 | 6.3 | 0.2 | 5.8 | 0.2
Race and Hispanic origin
Black or African American only, not Hispanic or Latino | 21.3 | 0.6 | 11.1 | 0.4 | 8.8 | 0.4
Asian only | 18.7 | 1.3 | 11.4 | 1.0 | 5.7 | 0.7
White only, not Hispanic or Latino | 15.6 | 0.3 | 7.6 | 0.2 | 7.1 | 0.2
Hispanic or Latino (total) | 38.2 | 0.7 | 28.4 | 0.6 | 8.9 | 0.3
Mexican | 41.2 | 0.8 | 31.5 | 0.8 | 8.9 | 0.4
Cuban | 24.9 | 2.1 | 18.3 | 2.0 | 6.3 | 1.2
Puerto Rican | 24.2 | 1.8 | 14.2 | 1.5 | 9.2 | 1.2

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Total uninsured prior to interview includes 1.1% of people with unknown length of time uninsured. Persons of Hispanic origin may be of any race. Total for Hispanic includes groups not shown separately. Asian only race includes persons of Hispanic and non-Hispanic origin. Uninsured persons are not covered by private insurance, Medicaid, State Children's Health Insurance Program (SCHIP), state-sponsored or other government-sponsored health plans, Medicare, or military plans. Persons with Indian Health Service only are considered uninsured. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 32% of persons under 65 years of age in 2004. See Appendix II, Family income; Health insurance coverage, length of time uninsured; Hispanic origin; Poverty; Race.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 8. National health expenditures as a percentage of Gross Domestic Product: United States, 1960–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig08.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig08.ppt)

NOTE: See Chartbook Figure 8.

Year | Percent
1960 | 5.2
1965 | 5.9
1970 | 7.2
1975 | 8.2
1980 | 9.1
1985 | 10.5
1990 | 12.4
1991 | 13.1
1992 | 13.5
1993 | 13.8
1994 | 13.7
1995 | 13.8
1996 | 13.7
1997 | 13.6
1998 | 13.7
1999 | 13.7
2000 | 13.8
2001 | 14.6
2002 | 15.4
2003 | 15.9
2004 | 16.0

NOTES: See related Table 120. See Appendix I, National Health Accounts.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Accounts.

Data table for Figure 9. Personal health care expenditures, by source of funds and type of expenditures: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig09.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig09.ppt)

NOTE: See Chartbook Figure 9.

| Type of expenditures
Personal health care expenditures and source of funds | Total | Hospital care | Physician services | Nursing home | Prescription drugs | Other
| Amount in billions
All personal health care expenditures | $1,560.2 | $570.8 | $399.9 | $115.2 | $188.5 | $285.9
| Percent distribution
All personal health care expenditures | 100.0 | 36.6 | 25.6 | 7.4 | 12.1 | 18.3
Source of funds | Percent distribution
All sources of funds | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0
Out-of-pocket payments | 15.1 | 3.3 | 10.0 | 27.7 | 24.9 | 34.4
Private health insurance | 36.1 | 35.6 | 48.5 | 7.8 | 47.6 | 23.5
Other private funds | 4.4 | 4.9 | 6.9 | 3.6 | 0.0 | 3.2
Government | 44.4 | 56.3 | 34.6 | 60.8 | 27.5 | 38.9
Medicaid | 17.5 | 17.3 | 6.9 | 44.3 | 19.3 | 20.1
Medicare | 19.2 | 28.6 | 20.5 | 13.9 | 1.8 | 12.2
Other government | 7.7 | 10.4 | 7.2 | 2.6 | 6.4 | 6.3
Federal | 33.9 | 45.3 | 28.5 | 42.0 | 16.9 | 26.9
State and local | 10.5 | 10.9 | 6.1 | 18.8 | 10.6 | 12.0

NOTES: Other expenditures include dental services, other professional services, home health care, nonprescription drugs and other medical nondurables, vision products and other medical durables, and other personal health care, not shown separately. See related Tables 123–124. See Appendix I, National Health Accounts.

SOURCE: Centers for Medicare & Medicaid Services, Office of the Actuary, National Health Statistics Group, National Health Accounts.

Data table for Figure 10. Cigarette smoking among men, women, high school students, and mothers during pregnancy: United States, 1965–2005 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig10.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig10.ppt)

NOTE: See Chartbook Figure 10.

| Men | | Women | | High school students | | Mothers during pregnancy
Year | Percent | SE | Percent | SE | Percent | SE | Percent
1965 | 51.2 | 0.3 | 33.7 | 0.3 | - - - | - - - | - - -
1974 | 42.8 | 0.5 | 32.2 | 0.4 | - - - | - - - | - - -
1979 | 37.0 | 0.5 | 30.1 | 0.5 | - - - | - - - | - - -
1983 | 34.8 | 0.6 | 29.4 | 0.4 | - - - | - - - | - - -
1985 | 32.2 | 0.5 | 27.9 | 0.4 | - - - | - - - | - - -
1987 | 30.9 | 0.4 | 26.5 | 0.4 | - - - | - - - | - - -
1988 | 30.3 | 0.4 | 25.7 | 0.3 | - - - | - - - | - - -
1989 | - - - | - - - | - - - | - - - | - - - | - - - | 19.5
1990 | 28.0 | 0.4 | 22.9 | 0.3 | - - - | - - - | 18.4
1991 | 27.6 | 0.4 | 23.5 | 0.3 | 27.5 | 1.4 | 17.8
1992 | 28.1 | 0.5 | 24.6 | 0.5 | - - - | - - - | 16.9
1993 | 27.3 | 0.6 | 22.6 | 0.4 | 30.5 | 1.0 | 15.8
1994 | 27.6 | 0.5 | 23.1 | 0.5 | - - - | - - - | 14.6
1995 | 26.5 | 0.6 | 22.7 | 0.5 | 34.8 | 1.2 | 13.9
1996 | - - - | - - - | - - - | - - - | - - - | - - - | 13.6
1997 | 27.1 | 0.4 | 22.2 | 0.4 | 36.4 | 1.1 | 13.2
1998 | 25.9 | 0.4 | 22.1 | 0.4 | - - - | - - - | 12.9
1999 | 25.2 | 0.5 | 21.6 | 0.4 | 34.8 | 1.3 | 12.6
2000 | 25.2 | 0.4 | 21.1 | 0.4 | - - - | - - - | 12.2
2001 | 24.6 | 0.4 | 20.7 | 0.4 | 28.5 | 1.0 | 12.0
2002 | 24.6 | 0.4 | 20.0 | 0.4 | - - - | - - - | 11.4
2003 | 23.7 | 0.4 | 19.4 | 0.4 | 21.9 | 1.1 | 10.7
2004 | 23.0 | 0.4 | 18.7 | 0.4 | - - - | - - - | 10.2
2005 | - - - | - - - | - - - | - - - | 23.0 | 1.2 | - - -

SE is standard error.

- - - Data not available.

NOTES: Data for men and women are for the civilian noninstitutionalized population. Estimates for men and women are age adjusted to the 2000 standard population using five age groups: 18–24 years, 25–34 years, 35–44 years, 45–64 years, and 65 years and over. Age-adjusted estimates in this table may differ from other age-adjusted estimates based on the same data and presented elsewhere if different age groups are used in the adjustment procedure. Cigarette smoking is defined as follows: among men and women 18 years and over, those who ever smoked 100 cigarettes in their lifetime and now smoke every day or some days; among high school students in grades 9–12, those who smoked cigarettes on 1 or more of the 30 days preceding the survey; and among mothers with a live birth, those who smoked during pregnancy. Data for mothers who smoked during pregnancy are based on the 1989 Revision of the U.S. Certificate of Live Birth. Some states did not require the reporting of mother's tobacco use during pregnancy on the birth certificate and are not included in this analysis. Reporting of tobacco use during pregnancy increased from 43 states and the District of Columbia (DC) in 1989 to 49 states and DC in 2000–2002. Starting with 2003 data, some reporting areas adopted the 2003 Revision of the U.S. Standard Certificate of Live Birth and 1 state continued to not report data. Tobacco use during pregnancy data based on the 2003 Revision are not comparable with data based on the 1989 Revision of the U.S. Standard Certificate of Live Birth and are excluded from this analysis. See Appendix II, Age adjustment; Cigarette smoking; Tobacco use. See related Tables 12 and 63.

SOURCES: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey (data for men and women); National Vital Statistics System (data for mothers during pregnancy); National Center for Chronic Disease Prevention and Health Promotion, Youth Risk Behavior Survey (data for high school students).

Data table for Figure 11. Binge drinking and current marijuana use among high school students, by sex, grade level, and year: United States, 1991, 1993, 2003, and 2005 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig11.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig11.ppt)

NOTE: See Chartbook Figure 11.

| Binge drinking | | Current marijuana use
Sex, grade level, and year | Percent | SE | Percent | SE
Both sexes
Attended grades 9–10 in 1991 | 24.8 | 1.6 | 11.5 | 1.1
Attended grades 11–12 in 1993 | 35.4 | 1.4 | 20.3 | 1.3
Attended grades 9–10 in 2003 | 23.4 | 1.2 | 20.1 | 1.4
Attended grades 11–12 in 2005 | 30.1 | 1.5 | 21.9 | 1.0
Male
Attended grades 9–10 in 1991 | 28.2 | 2.0 | 13.0 | 1.3
Attended grades 11–12 in 1993 | 41.2 | 1.8 | 23.6 | 1.8
Attended grades 9–10 in 2003 | 22.9 | 1.3 | 22.5 | 1.6
Attended grades 11–12 in 2005 | 33.2 | 1.7 | 24.7 | 1.1
Female
Attended grades 9–10 in 1991 | 21.3 | 1.6 | 9.9 | 1.1
Attended grades 11–12 in 1993 | 29.2 | 1.3 | 16.7 | 1.3
Attended grades 9–10 in 2003 | 23.9 | 1.4 | 17.7 | 1.3
Attended grades 11–12 in 2005 | 27.0 | 1.6 | 19.0 | 1.4

SE is standard error.

NOTES: Binge drinking is drinking five or more drinks of alcohol in a row on one or more of the 30 days preceding the survey. Current marijuana use is using marijuana one or more times during the 30 days preceding the survey.

SOURCE: Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, National Youth Risk Behavior Survey.

Data table for Figure 12. Regular leisure-time physical activity among adults 18 years of age and over, by percent of poverty level, race and Hispanic origin: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig12.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig12.ppt)

NOTE: See Chartbook Figure 12.

Characteristic | Percent | SE
Below 100% of poverty level
Not Hispanic or Latino:
White only | 24.8 | 1.3
Black or African American only | 17.1 | 1.6
Hispanic | 15.5 | 1.3
100%–less than 200% of poverty level
Not Hispanic or Latino:
White only | 24.3 | 1.1
Black or African American only | 17.6 | 1.7
Hispanic | 17.0 | 1.2
200% or more of poverty level
Not Hispanic or Latino:
White only | 35.5 | 0.5
Black or African American only | 28.4 | 1.3
Hispanic | 29.3 | 1.3

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Data are age adjusted to the 2000 standard population using five age groups: 18–44 years, 45–54 years, 55–64 years, 65–74 years, and 75 years and over. Adults were asked about the frequency and duration of vigorous and light/moderate physical activity during leisure time. Adults classified with regular leisure-time physical activity reported 3 or more sessions per week of vigorous activity of at least 20 minutes duration or 5 or more sessions per week of light/moderate activity lasting at least 30 minutes in duration. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 35% of adults in 2004. See Appendix II, Age adjustment; Family income; Physical activity, leisure-time; Poverty. See related Table 72.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 13. Overweight and obesity, by age: United States, 1960–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig13.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig13.ppt)

NOTE: See Chartbook Figure 13.

| Children 6–11 years | | Adolescents 12–19 years | | Adults 20–74 years
| Overweight | | | | Overweight including obese | | Overweight but not obese | | Obese
Year | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE
1960–1962 | - - - | - - - | - - - | - - - | 44.8 | 1.0 | 31.5 | 0.5 | 13.3 | 0.6
1963–1965 | 4.2 | 0.4 | - - - | - - - | - - - | - - - | - - - | - - - | - - - | - - -
1966–1970 | - - - | - - - | 4.6 | 0.3 | - - - | - - - | - - - | - - - | - - - | - - -
1971–1974 | 4.0 | 0.5 | 6.1 | 0.6 | 47.7 | 0.7 | 33.1 | 0.6 | 14.6 | 0.5
1976–1980 | 6.5 | 0.6 | 5.0 | 0.5 | 47.4 | 0.8 | 32.3 | 0.6 | 15.1 | 0.5
1988–1994 | 11.3 | 1.0 | 10.5 | 0.9 | 56.0 | 0.9 | 32.7 | 0.6 | 23.3 | 0.7
1999–2000 | 15.1 | 1.4 | 14.8 | 0.9 | 64.1 | 1.9 | 33.1 | 1.1 | 31.0 | 1.5
2001–2002 | 16.3 | 1.6 | 16.7 | 1.1 | 65.7 | 0.9 | 33.6 | 1.1 | 32.1 | 1.2
2003–2004 | 18.8 | 1.3 | 17.4 | 1.7 | 67.1 | 1.3 | 33.2 | 1.1 | 33.9 | 1.3

SE is standard error.

- - - Data not available.

NOTES: Data are for the civilian noninstitutionalized population. Estimates for adults are age adjusted to the 2000 standard population using five age groups: 20–34 years, 35–44 years, 45–54 years, 55–64 years, and 65–74 years. Age-adjusted estimates in this table may differ from other age-adjusted estimates based on the same data and presented elsewhere if different age groups are used in the adjustment procedure. For children and adolescents: overweight is defined as a body mass index (BMI) at or above the sex- and age-specific 95th percentile BMI cut points from the 2000 CDC Growth Charts: United States (See www.cdc.gov/growthcharts/); obese is not defined for children. For adults: overweight including obese is defined as a BMI greater than or equal to 25; overweight but not obese as a BMI greater than or equal to 25 but less than 30; and obese as a BMI greater than or equal to 30. Data for 1966–1970 are for adolescents 12–17 years, not 12–19 years. Pregnant adolescents were excluded beginning in 1971–1974. Pregnant women 20 years of age and over were excluded in all years. See Appendix II, Age adjustment; Body mass index (BMI). See related Tables 73 and 74.

SOURCES: Centers for Disease Control and Prevention, National Center for Health Statistics. National Health Examination Survey and National Health and Nutrition Examination Survey.

Data table for Figure 14. Untreated dental caries among children, by age, race and Hispanic origin: United States, 1971–2002 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig14.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig14.ppt)

NOTE: See Chartbook Figure 14.

| 1971–1974 | | 1988–1994 | | 1999–2002
Characteristic | Percent | SE | Percent | SE | Percent | SE
| Children 2–17 years
Total | 48.3 | 1.5 | 22.4 | 0.9 | 21.0 | 1.0
Race and Hispanic origin
Not Hispanic or Latino:
White | 45.7 | 1.5 | 17.6 | 1.0 | 17.4 | 1.8
Black or African American | 61.0 | 2.6 | 30.6 | 1.4 | 26.9 | 1.3
Mexican | 53.7 | 4.2 | 36.1 | 1.6 | 31.9 | 1.4
| Children 2–5 years
Total | 25.0 | 1.7 | 19.1 | 1.2 | 19.3 | 1.6
Race and Hispanic origin
Not Hispanic or Latino:
White | 23.7 | 1.8 | 13.8 | 1.6 | 16.9 | 2.1
Black or African American | 29.0 | 3.2 | 24.7 | 1.9 | 24.1 | 2.6
Mexican | 34.1 | 6.5 | 34.9 | 1.7 | 31.4 | 1.8
| Children 6–17 years
Total | 54.8 | 1.6 | 23.6 | 1.2 | 21.5 | 1.1
Race and Hispanic origin
Not Hispanic or Latino:
White | 51.9 | 1.6 | 18.9 | 1.2 | 17.5 | 2.0
Black or African American | 70.1 | 3.3 | 32.8 | 1.5 | 27.7 | 1.2
Mexican | 60.2 | 7.7 | 36.6 | 2.1 | 32.0 | 1.5

SE is standard error.

NOTES: Untreated dental caries refers to untreated coronal caries, that is, caries on the crown or enamel surface of the tooth. Root caries are not included. For children 2–5 years of age, only dental caries in primary teeth was evaluated. Caries in both permanent and primary teeth was evaluated for children 6–11 years of age. For children 12–17 years of age, only dental caries in permanent teeth was evaluated. Total includes children of all other races and Hispanic origins not shown separately. Persons of Mexican origin may be of any race. Starting with 1999 data, race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity and are not strictly comparable with estimates for earlier years. See Appendix II, Dental caries; Hispanic origin; Race. See related Table 75.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

Data table for Figure 15. Three or more chronic conditions among adults 45 years of age and over, by age and percent of poverty level: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig15.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig15.ppt)

NOTE: See Chartbook Figure 15.

| 45–54 years | | 55–64 years | | 65–74 years | | 75 years and over
Percent of poverty level | Percent | SE | Percent | SE | Percent | SE | Percent | SE
Total | 7.3 | 0.4 | 17.2 | 0.7 | 28.2 | 1.0 | 35.9 | 1.1
Below 100% | 17.3 | 1.7 | 31.3 | 2.5 | 37.0 | 3.0 | 38.2 | 3.1
100%–less than 200% | 12.2 | 1.6 | 25.7 | 2.1 | 32.9 | 2.1 | 36.7 | 1.8
200%–less than 400% | 6.0 | 0.7 | 17.1 | 1.3 | 27.7 | 1.7 | 35.4 | 1.8
400% or more | 5.2 | 0.5 | 12.0 | 0.9 | 22.6 | 1.7 | 33.9 | 2.8

SE is standard error.

NOTES: Chronic health conditions, except for asthma, were determined by asking if a doctor or health professional ever told the respondent that he or she had a specified condition. Current asthma was determined by asking if a doctor or health professional ever told the respondent he or she had asthma and whether the respondent still had asthma. The health measure, three or more chronic conditions, includes three or more of the following conditions: hypertension, heart disease, stroke, emphysema, diabetes, cancer, arthritis and related diseases, or current asthma. Heart disease includes coronary heart disease, angina or angina pectoris, heart attack or myocardial infarction, and any other kind of heart condition or heart disease. Diabetes includes all types with the exception of diabetic conditions related to pregnancy. Cancer includes all types with the exception of non-melanoma skin cancer. Arthritis includes arthritis, rheumatoid arthritis, gout, lupus, or fibromyalgia. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 37% of adults 45 years of age and over in 2004. See Appendix II, Condition; Family income; Poverty.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 16. Selected chronic health conditions causing limitation of activity among children, by age: United States, 2003–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig16.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig16.ppt)

NOTE: See Chartbook Figure 16.

| Under 5 years | | 5–11 years | | 12–17 years
Type of chronic health condition | Rate | SE | Rate | SE | Rate | SE
| Number of children with limitation of activity caused by selected chronic health conditions per 1,000 population
Speech problem | 10.4 | 1.0 | 19.0 | 1.2 | 5.2 | 0.6
Asthma or breathing problem | 7.2 | 0.8 | 6.8 | 0.7 | 5.7 | 0.6
Mental retardation or other developmental problem | 7.5 | 0.9 | 10.8 | 0.9 | 9.8 | 0.9
Other mental, emotional, or behavioral problem | 3.4 | 0.6 | 13.1 | 1.1 | 15.4 | 1.2
Attention Deficit/Hyperactivity Disorder | *1.9 | 0.5 | 18.7 | 1.2 | 21.9 | 1.3
Learning disability | 2.7 | 0.5 | 19.6 | 1.2 | 29.1 | 1.5

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20% to 30%.

NOTES: Data are for noninstitutionalized children. Children with limitation of activity caused by chronic health conditions were either identified by enrollment in special programs (special education or early intervention services) or by a limitation in their ability to perform activities usual for their age group because of a physical, mental, or emotional problem. Conditions refer to response categories in the National Health Interview Survey. Children who were reported to have more than one chronic health condition as the cause of their activity limitation were counted in each reported category. Starting in 2001, the condition list for children was expanded to include categories for Attention Deficit/Hyperactivity Disorder (ADHD or ADD) and learning disability. Thus, comparable data for this figure are not available prior to 2001. See Appendix II, Condition; Limitation of activity. See related Table 58.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 17. Selected chronic health conditions causing limitation of activity among working-age adults, by age: United States, 2003–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig17.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig17.ppt)

NOTE: See Chartbook Figure 17.

| 18–44 years | | 45–54 years | | 55–64 years
Type of chronic health condition | Rate | SE | Rate | SE | Rate | SE
| Number of persons with limitation of activity caused by selected chronic health conditions per 1,000 population
Mental illness | 13.3 | 0.5 | 20.9 | 1.0 | 21.7 | 1.3
Fractures or joint injury | 6.6 | 0.4 | 13.1 | 0.8 | 18.2 | 1.1
Lung | 5.0 | 0.3 | 11.6 | 0.8 | 23.0 | 1.3
Diabetes | 2.4 | 0.2 | 13.9 | 0.8 | 34.1 | 1.5
Heart or other circulatory | 5.4 | 0.3 | 26.0 | 1.1 | 72.1 | 2.3
Arthritis or other musculoskeletal | 20.8 | 0.7 | 59.1 | 1.6 | 97.7 | 2.7

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Conditions refer to response categories in the National Health Interview Survey; some conditions include several response categories. Mental illness includes depression, anxiety or emotional problem, and other mental conditions. Heart or other circulatory includes heart problem, stroke problem, hypertension or high blood pressure, and other circulatory system conditions. Arthritis or other musculoskeletal includes arthritis or rheumatism, back or neck problem, and other musculoskeletal system conditions. Persons may report more than one chronic health condition as the cause of their activity limitation. See related Table 58. See Appendix II, Condition; Limitation of activity.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 18. Selected chronic health conditions causing limitation of activity among older adults, by age: United States, 2003–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig18.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig18.ppt)

NOTE: See Chartbook Figure 18.

| 65–74 years | | 75–84 years | | 85 years and over
Type of chronic health condition | Rate | SE | Rate | SE | Rate | SE
| Number of persons with limitation of activity caused by selected chronic health conditions per 1,000 population
Senility | 7.1 | 0.8 | 31.6 | 2.2 | 97.8 | 7.0
Lung | 32.9 | 2.0 | 41.2 | 2.5 | 39.7 | 4.6
Diabetes | 42.6 | 1.9 | 49.1 | 2.7 | 47.2 | 5.2
Vision | 19.0 | 1.5 | 38.7 | 2.5 | 82.8 | 6.6
Hearing | 9.9 | 1.0 | 24.1 | 1.9 | 66.7 | 5.7
Heart or other circulatory | 100.9 | 3.3 | 156.7 | 5.0 | 223.7 | 9.9
Arthritis or other musculoskeletal | 127.1 | 3.7 | 181.1 | 5.1 | 268.3 | 10.2

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Conditions refer to response categories in the National Health Interview Survey; some conditions include several response categories. Vision includes vision conditions or problems seeing and hearing includes hearing problems. Heart or other circulatory includes heart problem, stroke problem, hypertension or high blood pressure, and other circulatory system conditions. Arthritis or other musculoskeletal includes arthritis or rheumatism, back or neck problem, and other musculoskeletal system conditions. Senility is the term offered to respondents on a flashcard, but this category may include Alzheimer's disease or other types of dementia reported by the respondent. Persons may report more than one chronic health condition as the cause of their activity limitation. See related Table 58. See Appendix II, Condition; Limitation of activity.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 19. Dental visit in the past year among children, by age, race and Hispanic origin: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig19.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig19.ppt)

NOTE: See Chartbook Figure 19.

| 2004
Characteristic | Percent | SE
| Children 2–17 years
Total | 76.4 | 0.5
Race and Hispanic origin
Not Hispanic or Latino:
White only | 80.9 | 0.6
Black or African American only | 72.9 | 1.4
Hispanic | 65.3 | 1.1
Asian only | 73.8 | 2.7
| Children 2–5 years
Total | 53.7 | 1.1
Race and Hispanic origin
Not Hispanic or Latino:
White only | 55.6 | 1.6
Black or African American only | 47.8 | 3.4
Hispanic | 51.8 | 2.1
Asian only | * | *
| Children 6–17 years
Total | 83.8 | 0.5
Race and Hispanic origin
Not Hispanic or Latino:
White only | 88.7 | 0.6
Black or African American only | 80.4 | 1.4
Hispanic | 70.7 | 1.3
Asian only | 80.9 | 2.8

SE is standard error.

* Estimates are considered unreliable. Relative standard error greater than 30%.

NOTES: Total includes children of all races not shown separately. Persons of Hispanic origin may be of any race. Asian race includes children of Hispanic and non-Hispanic origin. See Appendix II, Dental visit; Hispanic origin; Race. See related Tables 75, 91, and Figure 14.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 20. Influenza vaccination during the past year among adults 50 years of age and over, by race and Hispanic origin: United States, 2003–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig20.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig20.ppt)

NOTE: See Chartbook Figure 20.

| Influenza vaccination during the past 12 months
| 50–64 years | | 65 years and over
Race and Hispanic origin | Percent | SE | Percent | SE
Total | 36.4 | 0.5 | 65.1 | 0.5
Hispanic or Latino | 27.5 | 1.3 | 50.1 | 1.9
Not Hispanic or Latino:
White only | 38.5 | 0.6 | 68.0 | 0.6
Black or African American only | 27.0 | 1.2 | 46.7 | 1.7

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Excludes Flu Mist. Persons of Hispanic origin may be of any race. See Appendix II, Hispanic origin; Race. See related Table 83.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 21. Emergency department visits for falls, by sex and age: United States, 2002–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig21.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig21.ppt)

NOTE: See Chartbook Figure 21.

| Emergency department visits for falls
| Both sexes | | | Male | | | Female
Age and disposition for fall visits | Average annual in thousands | Number per 10,000 population | SE | Average annual in thousands | Number per 10,000 population | SE | Average annual in thousands | Number per 10,000 population | SE
All ages:
All visits for falls | 7,857 | 275.0 | 8.0 | 3,607 | 258.6 | 8.5 | 4,249 | 290.7 | 10.0
Fall visits with severe visit disposition | 919 | 32.2 | 1.6 | 346 | 24.8 | 1.6 | 574 | 39.3 | 2.4
Under 18 years:
All visits for falls | 2,314 | 317.4 | 13.8 | 1,311 | 351.7 | 17.3 | 1,003 | 281.5 | 15.2
Fall visits with severe visit disposition | 85 | 11.6 | 1.9 | 49 | 13.1 | 2.4 | 36 | *10.1 | 2.7
18–44 years:
All visits for falls | 2,247 | 203.8 | 7.1 | 1,141 | 208.9 | 9.5 | 1,106 | 198.8 | 9.5
Fall visits with severe visit disposition | 97 | 8.8 | 1.2 | 61 | 11.2 | 1.9 | 36 | *6.5 | 1.4
45–64 years:
All visits for falls | 1,377 | 201.9 | 8.2 | 526 | 158.9 | 9.3 | 852 | 242.4 | 12.2
Fall visits with severe visit disposition | 140 | 20.6 | 2.0 | 68 | 20.6 | 2.9 | 72 | 20.6 | 2.7
65–74 years:
All visits for falls | 564 | 311.6 | 17.9 | 234 | 283.5 | 27.7 | 331 | 335.1 | 22.7
Fall visits with severe visit disposition | 127 | 69.9 | 8.2 | 47 | *57.4 | 11.9 | 79 | 80.4 | 11.3
75–84 years:
All visits for falls | 743 | 606.5 | 31.6 | 243 | 488.4 | 36.5 | 501 | 687.1 | 46.1
Fall visits with severe visit disposition | 224 | 182.6 | 16.4 | 74 | 149.7 | 22.4 | 149 | 205.1 | 20.9
85 years and over:
All visits for falls | 611 | 1,554.3 | 93.8 | 153 | 1,178.1 | 124.9 | 458 | 1,740.1 | 123.1
Fall visits with severe visit disposition | 247 | 627.8 | 53.8 | 46 | 355.2 | 48.0 | 201 | 762.3 | 78.9

| Both sexes | | Male | | Female
Age and disposition for fall visits | Fall visits as a percent of all emergency department visits | SE | Fall visits as a percent of all emergency department visits | SE | Fall visits as a percent of all emergency department visits | SE
All ages:
All visits for falls | 7.1 | 0.1 | 7.0 | 0.2 | 7.1 | 0.2
Fall visits with severe visit disposition | 0.8 | 0.0 | 0.7 | 0.0 | 1.0 | 0.1
Under 18 years:
All visits for falls | 8.3 | 0.3 | 8.9 | 0.4 | 7.6 | 0.3
Fall visits with severe visit disposition | 0.3 | 0.0 | 0.3 | 0.1 | *0.3 | 0.1
18–44 years:
All visits for falls | 4.9 | 0.1 | 5.7 | 0.2 | 4.3 | 0.2
Fall visits with severe visit disposition | 0.2 | 0.0 | 0.3 | 0.1 | *0.1 | 0.0
45–64 years:
All visits for falls | 6.6 | 0.2 | 5.4 | 0.3 | 7.6 | 0.3
Fall visits with severe visit disposition | 0.7 | 0.1 | 0.7 | 0.1 | 0.6 | 0.1
65–74 years:
All visits for falls | 8.4 | 0.4 | 7.6 | 0.6 | 9.1 | 0.6
Fall visits with severe visit disposition | 1.9 | 0.2 | *1.5 | 0.3 | 2.2 | 0.3
75–84 years:
All visits for falls | 11.4 | 0.5 | 9.1 | 0.6 | 12.9 | 0.7
Fall visits with severe visit disposition | 3.4 | 0.3 | 2.8 | 0.4 | 3.8 | 0.4
85 years and over:
All visits for falls | 18.3 | 0.8 | 13.9 | 1.3 | 20.5 | 1.1
Fall visits with severe visit disposition | 7.4 | 0.5 | 4.2 | 0.5 | 9.0 | 0.8

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20% to 30%.

0.0 Quantity more than zero but less than 0.05.

NOTES: Visits for falls had a first-listed external cause of injury code of E880–886, E888, E957, E968.1, and E987. Severe visit disposition is an emergency department visit resulting in a hospital admission, transfer to another facility, or the person died in the emergency department. In 2002–2004, 85% of visits with a severe disposition outcome were hospitalized, 15% were transferred to another facility, and less than 1% died in the emergency department.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Ambulatory Medical Care Survey.

Data table for Figure 22. Visits to physician offices and hospital outpatient departments, by sex and age: United States, 1997–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig22.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig22.ppt)

NOTE: See Chartbook Figure 22.

Sex and age | 1997–1998 | 1999–2000 | 2001–2002 | 2003–2004
Both sexes | Average annual visits in thousands
Total | 884,528 | 874,094 | 1,041,286 | 998,226
Under 18 years | 183,286 | 170,960 | 202,661 | 194,133
18–44 years | 279,065 | 263,239 | 293,581 | 276,862
45–54 years | 118,642 | 125,585 | 155,717 | 149,219
55–64 years | 97,214 | 104,594 | 129,279 | 134,179
65–74 years | 107,784 | 104,786 | 127,813 | 117,042
75 years and over | 98,538 | 104,930 | 132,235 | 126,791
Male
Total | 352,838 | 356,872 | 420,251 | 407,032
Under 18 years | 95,027 | 88,472 | 103,545 | 101,578
18–44 years | 87,262 | 88,808 | 96,590 | 86,681
45–54 years | 45,426 | 49,325 | 61,611 | 60,670
55–64 years | 42,356 | 44,327 | 52,493 | 55,975
65–74 years | 45,399 | 45,106 | 55,434 | 50,878
75 years and over | 37,368 | 40,834 | 50,578 | 51,250
Female
Total | 531,691 | 517,222 | 621,035 | 591,194
Under 18 years | 88,260 | 82,488 | 99,115 | 92,555
18–44 years | 191,804 | 174,431 | 196,991 | 190,182
45–54 years | 73,216 | 76,260 | 94,106 | 88,549
55–64 years | 54,858 | 60,266 | 76,787 | 78,204
65–74 years | 62,385 | 59,681 | 72,379 | 66,164
75 years and over | 61,169 | 64,096 | 81,657 | 75,541

Sex and age | Rate | SE | Rate | SE | Rate | SE | Rate | SE
Both sexes | Number of visits per 100 persons
Total | 330.0 | 9.5 | 318.6 | 10.8 | 369.8 | 9.4 | 347.9 | 10.1
Under 18 years | 255.8 | 9.0 | 236.9 | 11.4 | 279.2 | 9.9 | 265.9 | 12.6
18–44 years | 257.5 | 8.8 | 241.7 | 9.9 | 266.8 | 8.6 | 251.1 | 9.4
45–54 years | 349.8 | 11.4 | 342.6 | 12.9 | 396.0 | 12.6 | 365.1 | 12.9
55–64 years | 443.7 | 15.6 | 442.0 | 16.4 | 501.1 | 15.9 | 473.6 | 17.5
65–74 years | 598.1 | 22.8 | 583.4 | 23.0 | 707.9 | 25.4 | 644.6 | 26.1
75 years and over | 694.3 | 30.4 | 700.3 | 28.1 | 837.8 | 33.0 | 777.4 | 34.0
Male
Total | 269.9 | 8.3 | 267.0 | 9.2 | 306.1 | 8.3 | 290.3 | 9.1
Under 18 years | 259.2 | 9.9 | 239.6 | 11.8 | 278.9 | 10.1 | 272.2 | 13.8
18–44 years | 163.1 | 6.2 | 165.4 | 7.5 | 177.7 | 7.3 | 158.5 | 6.1
45–54 years | 274.5 | 10.6 | 275.9 | 11.7 | 321.1 | 12.3 | 303.8 | 12.9
55–64 years | 405.5 | 16.4 | 392.1 | 16.7 | 424.5 | 15.4 | 411.4 | 18.4
65–74 years | 560.6 | 25.2 | 555.9 | 23.7 | 676.9 | 26.4 | 614.8 | 25.6
75 years and over | 682.5 | 32.8 | 707.6 | 30.3 | 834.2 | 34.5 | 809.4 | 38.2
Female
Total | 387.1 | 11.5 | 367.7 | 12.9 | 430.5 | 11.5 | 402.9 | 12.0
Under 18 years | 252.3 | 9.0 | 234.1 | 11.6 | 279.5 | 10.8 | 259.4 | 12.2
18–44 years | 349.4 | 13.2 | 315.9 | 13.8 | 353.9 | 12.4 | 342.2 | 14.6
45–54 years | 421.6 | 15.0 | 406.2 | 16.3 | 467.4 | 15.9 | 423.5 | 15.6
55–64 years | 478.6 | 17.6 | 487.8 | 19.0 | 571.5 | 20.1 | 531.1 | 19.8
65–74 years | 628.8 | 25.1 | 606.0 | 26.4 | 733.7 | 29.7 | 669.7 | 30.8
75 years and over | 701.7 | 32.3 | 695.7 | 29.5 | 840.1 | 37.4 | 757.1 | 35.2

SE is standard error.

NOTES: For 1997–1999 data, population estimates are 1990-based postcensal estimates as of July 1 and are adjusted for net underenumeration using the 1990 National Population Adjustment Matrix from the U.S. Census Bureau. Starting with 2000 data, population estimates are based on the 2000 census. See Appendix I, Population Census and Population Estimates. See related Table 89. Starting with Health, United States, 2005, data from 2001 and onwards use a revised weighting scheme. See Appendix I, National Ambulatory Medical Care Survey.

SOURCES: Centers for Disease Control and Prevention, National Center for Health Statistics, National Ambulatory Medical Care Survey, and National Hospital Ambulatory Medical Care Survey.

Data table for Figure 23. Average annual hospital inpatient gastric bypass and other bariatric procedures among adults 18–64 years of age with obesity, by sex and age: United States, 1996–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig23.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig23.ppt)

NOTE: See Chartbook Figure 23.

| 1996–1998 | 1999–2001 | 2002–2004
Sex and age | Number | Number | Number
| Average annual
Both sexes
18–64 years | *11,111 | 30,475 | 106,242
18–44 years | *6,927 | 19,067 | 63,602
45–64 years | *4,184 | 11,409 | 42,640
Men
18–64 years | *1,789 | 4,570 | 17,134
18–44 years | * | *1,871 | 9,246
45–64 years | * | *2,699 | 7,888
Women
18–64 years | *9,322 | 25,905 | 89,108
18–44 years | *6,083 | 17,196 | 54,356
45–64 years | *3,239 | 8,709 | 34,751

*Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20% to 30%. Data not shown have an RSE of greater than 30%.

NOTES: Obesity is defined as diagnosis codes 278.00 or 278.01 on the discharge record. Up to four procedures were coded for each non-federal hospital stay. Data in this table are for any listed procedure; if more than one bariatric procedure is performed during the same hospital stay, it is counted only once. Procedures codes 44.31, 44.39, 44.69 define bariatric surgery. Starting with 2003 data, procedure codes 43.7, 43.89, 45.51, and 45.91 are also included. In addition to these seven codes, the 2004 data define bariatric surgery using procedures codes 44.68, 44.95, 44.96, 44.97, and 44.98. Procedure groupings and code numbers are based on the International Classification of Diseases, 9th Revision, Clinical Modification (ICD–9–CM). Data on adults age 65 and over are considered unreliable because of the small number of procedures performed and therefore are not presented. See Appendix II, International Classification of Diseases, 9th Revision,Clinical Modification (ICD–9–CM).

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Discharge Survey.

Data table for Figure 24. Life expectancy at birth and at 65 years of age, by sex: United States, 1900–2003 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig24.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig24.ppt)

NOTE: See Chartbook Figure 24.

| At birth | | At 65 years
Year | Male | Female | Male | Female
| Life expectancy in years
1900–1902 | 47.9 | 50.7 | 11.5 | 12.2
1909–1911 | 49.9 | 53.2 | 11.2 | 12.0
1919–1921 | 55.5 | 57.4 | 12.2 | 12.7
1929–1931 | 57.7 | 60.9 | 11.7 | 12.8
1939–1941 | 61.6 | 65.9 | 12.1 | 13.6
1949–1951 | 65.5 | 71.0 | 12.7 | 15.0
1959–1961 | 66.8 | 73.2 | 13.0 | 15.8
1969–1971 | 67.0 | 74.6 | 13.0 | 16.8
1979–1981 | 70.1 | 77.6 | 14.2 | 18.4
1989–1991 | 71.8 | 78.8 | 15.1 | 19.0
1997 | 73.6 | 79.4 | 15.9 | 19.2
1998 | 73.8 | 79.5 | 16.0 | 19.2
1999 | 73.9 | 79.4 | 16.1 | 19.1
2000 | 74.3 | 79.7 | 16.2 | 19.3
2001 | 74.4 | 79.8 | 16.4 | 19.4
2002 | 74.5 | 79.9 | 16.6 | 19.5
2003 | 74.8 | 80.1 | 16.8 | 19.8

NOTES: Death rates used to calculate life expectancies for 1997–1999 are based on postcensal 1990-based population estimates; life expectancies for 2000 and beyond are calculated with death rates based on census 2000. See Appendix I, Population Census and Population Estimates. Life expectancies prior to 1997 are from decennial life tables based on census data and deaths for a 3-year period around the census year. The middle year in each 3-year period is plotted in Figure 24. Beginning in 1997, the annual life tables are complete life tables based on a methodology similar to that used for decennial life tables. Alaska and Hawaii were included beginning in 1959. For decennial periods prior to 1929–31, data are limited to death registration states: 1900–1902 and 1909–1911, 10 states and the District of Columbia; 1919–1921, 34 states and the District of Columbia. Deaths to nonresidents were excluded beginning in 1970. See Appendix II, Life expectancy. See related Table 27.

SOURCE: Arias, E. United States life tables, 2003. National vital statistics reports; vol 54 no 14. Hyattsville, MD: National Center for Health Statistics. 2006.

Data table for Figure 25. Infant, neonatal, and postneonatal mortality rates: United States, 1950–2003 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig25.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig25.ppt)

NOTE: See Chartbook Figure 25.

Year | Infant | Neonatal | Postneonatal
| Deaths per 1,000 live births
1950 | 29.2 | 20.5 | 8.7
1960 | 26.0 | 18.7 | 7.3
1970 | 20.0 | 15.1 | 4.9
1980 | 12.6 | 8.5 | 4.1
1985 | 10.6 | 7.0 | 3.7
1990 | 9.2 | 5.8 | 3.4
1995 | 7.6 | 4.9 | 2.7
1996 | 7.3 | 4.8 | 2.5
1997 | 7.2 | 4.8 | 2.5
1998 | 7.2 | 4.8 | 2.4
1999 | 7.1 | 4.7 | 2.3
2000 | 6.9 | 4.6 | 2.3
2001 | 6.8 | 4.5 | 2.3
2002 | 7.0 | 4.7 | 2.3
2003 | 6.9 | 4.6 | 2.2

NOTES: Infant is defined as under 1 year of age, neonatal as under 28 days of age, and postneonatal as between 28 days and 1 year of age. See related Table 22.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System.

Data table for Figure 26. Infant mortality rates, by detailed race and Hispanic origin of mother: United States, 2001–2003 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig26.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig26.ppt)

NOTE: See Chartbook Figure 26.

Race and Hispanic origin of mother | Infant deaths per 1,000 live births
White, not Hispanic or Latino | 5.7
Black or African American, not Hispanic or Latino | 13.6
Hispanic or Latino | 5.6
Puerto Rican | 8.3
Other and unknown Hispanic or Latino | 6.6
Mexican | 5.4
Central and South American | 5.0
Cuban | 4.2
Asian or Pacific Islander | 4.8
American Indian or Alaska Native | 8.9

NOTES: Infant is defined as under 1 year of age. Persons of Hispanic origin may be of any race. Asian or Pacific Islander and American Indian or Alaska Native races include persons of Hispanic and non-Hispanic origin. Starting in 2003, some states reported multiple-race data. The multiple-race data for these states were bridged to the single race categories of the 1977 Office of Management and Budget standards for comparability with other states. Estimates are not shown for Asian or Pacific Islander subgroups during the transition from single race to multiple race reporting. See Appendix II, Hispanic origin; Race. See related Table 19.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System, National Linked Birth/Infant Death Data Sets.

Data table for Figure 27. Death rates for leading causes of death for all ages: United States, 1950–2003 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig27.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig27.ppt)

NOTE: See Chartbook Figure 27.

Year | All causes | Heart disease | Cancer | Stroke | Chronic lower respiratory diseases | Unintentional injuries
| Deaths per 100,000 population
1950 | 1,446.0 | 586.8 | 193.9 | 180.7 | - - - | 78.0
1960 | 1,339.2 | 559.0 | 193.9 | 177.9 | - - - | 62.3
1970 | 1,222.6 | 492.7 | 198.6 | 147.7 | - - - | 60.1
1980 | 1,039.1 | 412.1 | 207.9 | 96.2 | 28.3 | 46.4
1985 | 988.1 | 375.0 | 211.3 | 76.4 | 34.5 | 38.5
1990 | 938.7 | 321.8 | 216.0 | 65.3 | 37.2 | 36.3
1995 | 909.8 | 293.4 | 209.9 | 63.1 | 40.1 | 34.4
1996 | 894.1 | 285.7 | 206.7 | 62.5 | 40.6 | 34.5
1997 | 878.1 | 277.7 | 203.4 | 61.1 | 41.1 | 34.2
1998 | 870.6 | 271.3 | 200.7 | 59.3 | 41.8 | 34.5
1998 (Comparability-modified) | 870.6 | 267.4 | 202.1 | 62.8 | 43.8 | 35.6
1999 | 875.6 | 266.5 | 200.8 | 61.6 | 45.4 | 35.3
2000 | 869.0 | 257.6 | 199.6 | 60.9 | 44.2 | 34.9
2001 | 854.5 | 247.8 | 196.0 | 57.9 | 43.7 | 35.7
2002 | 845.3 | 240.8 | 193.5 | 56.2 | 43.5 | 36.9
2003 | 832.7 | 232.3 | 190.1 | 53.5 | 43.3 | 37.3

- - - Data not available.

NOTES: Estimates are age adjusted to the year 2000 standard population using age groups from under 1 year, 1–4 years, 10-year age groups from 5–14 through 75–84 years, and 85 years and over. Causes of death shown are the five leading causes of death for all ages in 2003. The 1950 death rates are based on the 6th revision of the International Classification of Disease (ICD-6), 1960 death rates on the ICD-7, 1970 death rates on the ICDA-8, and 1980–1998 death rates on the ICD-9. The 1998 (comparability-modified) death rates use comparability ratios to adjust the rate to be comparable to records classified according to ICD-10. Starting with 1999 data, death rates are based on ICD-10. Comparability ratios across revisions for selected causes are available from: www.cdc.gov/nchs/data/statab/comp2.pdf. Death rates for chronic lower respiratory diseases are available from 1980 when a category that included bronchitis, emphysema, asthma, and other chronic lung diseases was introduced in ICD-9. Cancer refers to malignant neoplasms; stroke to cerebrovascular diseases; and unintentional injuries is preferred to the term, accidents, in the public health community. Rates for 1991–1999 were computed using intercensal population estimates based on the 2000 census. Rates for 2000 were computed using 2000 census counts. Rates for 2001 and beyond were computed using postcensal estimates based on the 2000 census. See Appendix I, Population Census and Population Estimates. See Appendix II, Age adjustment; Cause of death; Comparability ratio. See related Tables 29, 31, 35, 36, 37, 38, 39, and 41.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System.

Data table for Figure 28. Adults 20 years of age and over reporting pain in the month prior to interview, by selected characteristics: United States, 1999–2002 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig28.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig28.ppt)

NOTE: See Chartbook Figure 28.

Characteristic | Percent | SE
Age
20 years and over | 25.8 | 0.7
20–44 years | 25.1 | 0.9
45–64 years | 29.6 | 1.4
65 years and over | 21.0 | 0.9
Sex
Men | 24.4 | 0.8
Women | 27.1 | 0.9
Race and Hispanic origin
Not Hispanic or Latino:
White only | 27.8 | 0.8
Black only | 22.1 | 1.4
Mexican | 15.3 | 1.1
Percent of poverty level
Below 100% | 29.8 | 1.7
100%–less than 200% | 28.3 | 1.3
200% or more | 24.8 | 0.8

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Respondents were asked to report pain that lasted more than 24 hours in duration during the month prior to interview. Persons of Mexican origin may be of any race. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. See Appendix II, Family income; Hispanic origin; Poverty; Race.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

Data table for Figure 29. Duration of pain among adults reporting pain, by age: United States, 1999–2002 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig29.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig29.ppt)

NOTE: See Chartbook Figure 29.

| Less than 1 month | | 1 month to less than 3 months | | 3 months to less than 1 year | | 1 year or more
Age | Percent | SE | Percent | SE | Percent | SE | Percent | SE
20 years and over | 32.0 | 1.2 | 12.3 | 0.9 | 13.7 | 0.9 | 42.0 | 1.0
20–44 years | 39.1 | 1.9 | 11.9 | 1.6 | 12.5 | 1.6 | 36.5 | 1.8
45–64 years | 27.2 | 1.9 | 13.6 | 1.1 | 15.5 | 1.6 | 43.7 | 1.7
65 years and over | 18.9 | 2.2 | 10.4 | 1.4 | 13.4 | 2.2 | 57.3 | 1.6

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Respondents who reported pain lasting more than 24 hours in duration in the month prior to interview (see Figure 28), were asked a question about the duration of that pain. Percentages shown are among adults who reported pain.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

Data table for Figure 30. Adults reporting low back pain, migraine, neck, and face pain in the 3 months prior to interview, by age: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig30.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig30.ppt)

NOTE: See Chartbook Figure 30.

| Low back pain | | Severe headache or migraine | | Neck pain | | Face pain
Age | Percent | SE | Percent | SE | Percent | SE | Percent | SE
18 years and over | 27.2 | 0.3 | 15.3 | 0.3 | 14.8 | 0.3 | 4.3 | 0.1
18–44 years | 23.9 | 0.5 | 18.4 | 0.4 | 12.4 | 0.3 | 4.5 | 0.2
45–64 years | 30.8 | 0.5 | 15.0 | 0.4 | 18.7 | 0.5 | 4.7 | 0.2
65 years and over | 30.4 | 0.7 | 6.2 | 0.3 | 14.4 | 0.5 | 2.9 | 0.2

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Respondents were asked: "During the past 3 months, did you have neck pain? Or low back pain? Or facial ache or pain in the jaw muscles or the joint in front of the ear? Or severe headache or migraine?" Respondents were asked to report pain that lasted a whole day or more and to not report aches or pains that are fleeting or minor. Respondents reporting more than one type of pain were included in each category. See related Table 56.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 31. Adults 18 years of age and over reporting low back pain in the 3 months prior to interview, by selected characteristics: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig31.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig31.ppt)

NOTE: See Chartbook Figure 31.

| Total | | Men | | Women
Characteristic | Percent | SE | Percent | SE | Percent | SE
Age
18 years and over | 27.2 | 0.3 | 25.0 | 0.5 | 29.2 | 0.4
18–44 years | 23.9 | 0.5 | 22.0 | 0.6 | 25.8 | 0.6
45–64 years | 30.8 | 0.5 | 28.9 | 0.8 | 32.5 | 0.7
65 years and over | 30.4 | 0.7 | 27.2 | 1.1 | 32.8 | 0.9
Race and Hispanic origin
Hispanic | 22.1 | 0.7 | 18.5 | 0.9 | 25.8 | 1.0
Not Hispanic or Latino:
White only | 29.1 | 0.4 | 27.4 | 0.6 | 30.7 | 0.5
Black or African American only | 23.5 | 0.8 | 20.1 | 1.2 | 26.3 | 1.1
Asian only | 16.9 | 1.3 | 14.6 | 1.8 | 19.2 | 2.0
Percent of poverty level
Below 100% | 31.3 | 1.0 | 26.3 | 1.4 | 34.8 | 1.1
100%–less than 200% | 29.5 | 0.8 | 26.7 | 1.2 | 31.8 | 0.9
200% or more | 25.9 | 0.4 | 24.4 | 0.5 | 27.3 | 0.5

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Respondents were asked: "During the past 3 months, did you have low back pain?" Respondents were asked to report pain that lasted a whole day or more and to not report aches or pains that were fleeting or minor. Persons of Hispanic origin may be of any race. Asian only race includes persons of Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 35% of persons 18 years of age and over in 2004. See Appendix II, Family income; Hispanic origin; Poverty; Race. See related Table 56.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 32. Adults 18 years of age and over reporting joint pain in the 30 days prior to interview, by severity level and selected characteristics: United States, 2003 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig32.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig32.ppt)

NOTE: See Chartbook Figure 32.

| Any joint pain | | Severe joint pain | | Lesser joint pain
Characteristic | Percent | SE | Percent | SE | Percent | SE
Age
18 years and over | 31.4 | 0.4 | 8.4 | 0.2 | 23.0 | 0.3
18–44 years | 20.5 | 0.4 | 4.9 | 0.2 | 15.6 | 0.4
45–64 years | 39.9 | 0.6 | 11.5 | 0.4 | 28.5 | 0.6
65 years and over | 49.9 | 0.8 | 13.6 | 0.5 | 36.3 | 0.8
Sex
Men | 28.5 | 0.5 | 6.5 | 0.2 | 21.9 | 0.4
Women | 34.1 | 0.5 | 10.1 | 0.3 | 24.0 | 0.4
Race and Hispanic origin
Hispanic | 18.9 | 0.7 | 7.8 | 0.4 | 11.1 | 0.5
Not Hispanic or Latino:
White only | 34.7 | 0.4 | 8.2 | 0.2 | 26.5 | 0.4
Black only | 27.8 | 0.9 | 11.2 | 0.6 | 16.6 | 0.7
Asian only | 17.2 | 1.5 | 3.3 | 0.7 | 13.9 | 1.4
Percent of poverty level
Below 100% | 30.6 | 0.9 | 13.4 | 0.6 | 17.2 | 0.7
100%–less than 200% | 34.0 | 0.8 | 11.5 | 0.5 | 22.6 | 0.7
200% or more | 30.9 | 0.4 | 6.7 | 0.2 | 24.2 | 0.4

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Respondents were asked "During the past 30 days, have you had any symptoms of pain, aching, or stiffness in or around a joint?" Respondents, who reported joint symptoms, were asked "During the past 30 days, how bad was your joint pain on average?" Respondents were instructed to answer on a scale of 0–10 where 0 is no pain or aching and 10 is pain or aching as bad as it can be. In this analysis, lesser joint pain was defined as 0–6 and severe pain was defined as a response of 7–10. This analysis excludes a small number of adults who did not provide information on both joint pain questions. Persons of Hispanic origin may be of any race. Asian only race includes persons of Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 36% of persons 18 years of age and over in 2003. See Appendix II, Family income; Hispanic origin; Poverty; Race. See related Table 57.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.

Data table for Figure 33. Narcotic analgesic drug visits to the emergency department, by pain level, age, sex, and race: United States, average annual 2003–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig33.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig33.ppt)

NOTE: See Chartbook Figure 33.

| | | Narcotic analgesic drug visit by level of pain
| Emergency department visit with narcotic analgesic drugs | | No pain | | Mild pain | | Moderate pain | | Severe pain | | Unknown/ missing pain level
Age, sex, and race | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE
Total | 22.9 | 0.5 | 5.1 | 0.3 | 18.5 | 0.7 | 33.1 | 0.9 | 49.8 | 1.0 | 15.6 | 0.5
Age
Under 11 years | 4.1 | 0.3 | *1.4 | 0.3 | 4.4 | 0.7 | 9.1 | 1.1 | 16.7 | 2.3 | 2.9 | 0.3
11–17 years | 14.8 | 0.8 | *2.1 | 0.5 | 11.8 | 1.5 | 20.5 | 1.6 | 32.1 | 2.6 | 10.8 | 1.0
18–44 years | 30.2 | 0.7 | 6.7 | 0.6 | 23.0 | 0.9 | 37.8 | 1.1 | 52.8 | 1.3 | 22.7 | 0.9
45–64 years | 30.0 | 0.7 | 7.8 | 1.0 | 24.7 | 1.2 | 39.0 | 1.3 | 56.9 | 1.5 | 21.1 | 0.9
65 years and over | 19.7 | 0.6 | 5.6 | 0.5 | 19.8 | 1.3 | 32.9 | 1.6 | 46.0 | 1.8 | 15.1 | 0.8
Sex
Male | 21.6 | 0.5 | 5.1 | 0.5 | 18.1 | 0.9 | 32.6 | 1.0 | 50.3 | 1.3 | 14.3 | 0.5
Female | 24.0 | 0.6 | 5.1 | 0.4 | 18.9 | 0.9 | 33.6 | 1.0 | 49.5 | 1.1 | 16.7 | 0.6
Race
White | 24.4 | 0.5 | 5.3 | 0.4 | 19.9 | 0.8 | 35.3 | 0.9 | 53.0 | 1.1 | 16.6 | 0.5
Black | 18.2 | 0.6 | 4.3 | 0.6 | 14.2 | 1.0 | 26.3 | 1.5 | 39.5 | 1.8 | 12.3 | 0.8

SE is standard error.

* Data are considered unreliable. Data preceded by an asterisk have a relative standard error of 20% to 30%.

NOTES: The race groups include persons of Hispanic and non-Hispanic origin. Visits are classified as narcotic analgesic drug visits if at least one narcotic analgesic drug was prescribed or provided during the visit. For listing of narcotic analgesic drugs, see Appendix II, National Drug Code (NDC) Directory therapeutic class; Table XII. Estimates for race in this table are for visits where only one race was recorded. Estimates for visits where multiple races were checked are unreliable and not presented.

SOURCES: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Ambulatory Medical Care Survey, Emergency Department Component.

Data table for Figure 34. Adults 18 years of age and over reporting narcotic drug use in the month prior to interview, by sex, age, race and ethnicity: United States, 1988–1994 and 1999–2002 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig34.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig34.ppt)

NOTE: See Chartbook Figure 34.

| 1988–1994 | | 1999–2002
Characteristic | Percent | SE | Percent | SE
Both sexes
Total, age adjusted | 3.2 | 0.2 | 4.2 | 0.3
Total, crude | 3.2 | 0.2 | 4.2 | 0.3
18–44 years | 2.9 | 0.3 | 3.6 | 0.4
45–64 years | 3.3 | 0.4 | 4.6 | 0.7
65 years and over | 3.9 | 0.4 | 5.7 | 0.5
Not Hispanic or Latino:
White only | 3.4 | 0.3 | 4.6 | 0.4
Black or African American only | 3.4 | 0.2 | 3.8 | 0.7
Mexican | 3.3 | 0.3 | 2.9 | 0.4
Men
Total, age adjusted | 2.8 | 0.3 | 3.0 | 0.3
Total, crude | 2.7 | 0.3 | 3.0 | 0.3
18–44 years | 2.4 | 0.4 | 2.5 | 0.4
45–64 years | 3.3 | 0.6 | *3.4 | 0.7
65 years and over | 3.2 | 0.5 | 4.1 | 0.6
Not Hispanic or Latino:
White only | 2.9 | 0.4 | 3.3 | 0.4
Black or African American only | 2.8 | 0.4 | *2.9 | 0.7
Mexican | 3.3 | 0.5 | *2.7 | 0.6
Women
Total, age adjusted | 3.6 | 0.2 | 5.3 | 0.4
Total, crude | 3.6 | 0.2 | 5.4 | 0.4
18–44 years | 3.5 | 0.3 | 4.6 | 0.6
45–64 years | 3.3 | 0.5 | 5.7 | 0.8
65 years and over | 4.4 | 0.5 | 6.8 | 0.9
Not Hispanic or Latino:
White only | 3.8 | 0.3 | 5.9 | 0.5
Black or African American only | 3.8 | 0.5 | 4.5 | 0.8
Mexican | 3.3 | 0.4 | 3.2 | 0.5

SE is standard error.

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20% to 30%.

NOTES: Data are for the civilian noninstitutionalized population. Narcotic drugs are defined as drugs in NDC class 1721. Estimates for 2000 and later years use weights derived from the 2000 census. Total and race-ethnicity estimates are age adjusted to the 2000 standard population using three age groups: 18–44 years, 45–64 years, and 65 years and over. Persons of Mexican origin may be of any race. Starting with data year 1999, race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. See Appendix II, Age adjustment; Drugs; National Drug Code (NDC) Directory therapeutic class; Hispanic origin; Race.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health and Nutrition Examination Survey.

Data table for Figure 35. Hospital discharges for knee and nonfracture hip replacement surgery among adults 18 years of age and over, by sex and age: United States, 1992–1993 and 2003–2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig35.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig35.ppt)

NOTE: See Chartbook Figure 35.

| Knee replacement
| 1992–1993 | 1992–1993 | | 2003–2004 | 2003–2004
Sex and age | Average annual number of hospital discharges with procedure performed in thousands | Hospital discharges with procedure performed per 10,000 population | SE | Average annual number of hospital discharges with procedure performed in thousands | Hospital discharges with procedure performed per 10,000 population | SE
Both sexes
18 years and over | 166 | 8.7 | 0.6 | 428 | 19.7 | 1.4
18–44 years | 3 | 0.3 | 0.1 | 7 | 0.7 | 0.1
45–64 years | 38 | 7.8 | 0.7 | 158 | 22.7 | 1.8
65 years and over | 124 | 38.6 | 3.0 | 263 | 72.9 | 5.4
65–74 years | 74 | 40.4 | 3.5 | 145 | 78.7 | 6.0
75 years and over | 50 | 36.1 | 3.1 | 118 | 66.9 | 5.2
Men
18 years and over | 54 | 6.0 | 0.5 | 152 | 14.4 | 1.4
18–44 years | 2 | 0.3 | 0.1 | 3 | 0.5 | 0.1
45–64 years | 12 | 5.2 | 0.6 | 56 | 16.4 | 1.9
65 years and over | 40 | 30.7 | 2.5 | 94 | 62.3 | 6.9
65–74 years | 25 | 30.7 | 3.0 | 51 | 61.2 | 7.2
75 years and over | 15 | 30.8 | 3.3 | 42 | 63.7 | 7.4
Women
18 years and over | 111 | 11.2 | 0.9 | 276 | 24.5 | 1.6
18–44 years | 2 | 0.3 | 0.1 | 5 | 0.8 | 0.2
45–64 years | 26 | 10.2 | 1.2 | 102 | 28.6 | 2.4
65 years and over | 84 | 43.9 | 3.8 | 169 | 80.5 | 5.2
65–74 years | 49 | 48.1 | 5.0 | 93 | 93.4 | 6.4
75 years and over | 35 | 39.1 | 3.6 | 76 | 68.7 | 5.2

| Nonfracture hip replacement
| 1992–1993 | 1992–1993 | | 2003–2004 | 2003–2004
Sex and age | Average annual number of hospital stays with procedure performed in thousands | Hospital stays with procedure performed per 10,000 population | SE | Average annual number of hopital stays with procedure performed in thousands | Hospital stays with procedure performed per 10,000 population | SE
Both sexes
18 years and over | 126 | 6.6 | 0.5 | 282 | 13.0 | 1.1
18–44 years | 10 | 0.9 | 0.1 | 33 | 3.0 | 0.4
45–64 years | 35 | 7.1 | 0.7 | 107 | 15.3 | 1.5
65 years and over | 81 | 25.2 | 1.9 | 142 | 39.5 | 3.3
65–74 years | 44 | 24.0 | 1.9 | 72 | 39.2 | 3.8
75 years and over | 37 | 26.7 | 2.5 | 70 | 39.7 | 3.4
Men
18 years and over | 51 | 5.6 | 0.4 | 125 | 11.9 | 1.1
18–44 years | 6 | 1.0 | 0.2 | 17 | 3.1 | 0.4
45–64 years | 17 | 7.3 | 0.8 | 53 | 15.8 | 1.6
65 years and over | 28 | 21.2 | 1.8 | 54 | 36.2 | 3.5
65–74 years | 16 | 20.3 | 2.3 | 28 | 33.8 | 4.1
75 years and over | 11 | 22.8 | 2.7 | 26 | 39.2 | 4.2
Women
18 years and over | 75 | 7.6 | 0.7 | 157 | 14.0 | 1.2
18–44 years | 4 | 0.8 | 0.1 | 16 | 2.9 | 0.4
45–64 years | 17 | 6.9 | 0.9 | 53 | 14.9 | 1.6
65 years and over | 53 | 27.9 | 2.4 | 88 | 41.8 | 3.7
65–74 years | 28 | 27.0 | 2.5 | 44 | 43.7 | 4.4
75 years and over | 26 | 28.9 | 3.1 | 44 | 40.0 | 4.1

SE is standard error.

NOTES: Up to four inpatient hospital procedures were coded for each stay. Procedure codes are based on the International Classification of Diseases, Ninth Revision, Clinical Modification (knee replacement 81.54 and hip replacement 81.51–52, excluding hip fracture codes 820 and 733.14). In 2003–2004, 28% of hip replacements were for hip fracture. This table shows any-listed procedures; if more than one procedure with the same ICD code (e.g., hip replacement) is performed during the hospitalization it is counted only once. Rates are based on the civilian population as of July 1.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Hospital Discharge Survey.

Data table for Figure 36. Adults reporting ambulatory medical care use for headaches and associated ambulatory medical care expenses, by age and sex: United States 2002–2003 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig36.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig36.ppt)

NOTE: See Chartbook Figure 36.

Age and sex | Percent with ambulatory medical care for headaches | SE | Headache expenses per person with headache expense in dollars | SE
Age
18 years and over | 3.5 | 0.12 | $566 | $31
18–44 years | 3.4 | 0.16 | 516 | 46
45–64 years | 4.5 | 0.22 | 633 | 43
65 years and over | 1.9 | 0.21 | 536 | 92
Sex
Men | 1.6 | 0.12 | 552 | 66
Women | 5.3 | 0.19 | 570 | 34

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Estimates for 2002 have been adjusted to 2003 dollars using the Consumer Price Index (All Urban Consumers: U.S. City Average: All items). Ambulatory medical care is defined as having one or more visits to a medical provider (office-based, hospital outpatient and emergency department settings) and/or at least one prescribed medicine purchase during the year. ICD–9–CM codes 346, 784.0, and 307.81 were used to identify migraines and headaches.

SOURCE: Agency for Healthcare Research and Quality, Financing, Access, and Cost Trends, Household Component, Medical Expenditure Panel Survey.

Data table for Figure 37. Health status measures among adults 18 years of age and over with and without low back pain, by age: United States, 2004 Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus06figures/Fig37.xls) Click here for PowerPoint (http://www.cdc.gov/nchs/ppt/hus/HUS06fig37.ppt)

NOTE: See Chartbook Figure 37.

| Low back pain in the 3 months prior to interview | | No low back pain in the 3 months prior to interview
Health status measure and age | Percent | SE | Percent | SE
Limitation of activity caused by chronic conditions
18 years and over | 28.1 | 0.6 | 9.6 | 0.2
18–44 years | 14.8 | 0.7 | 4.1 | 0.2
45–64 years | 32.4 | 1.0 | 10.5 | 0.4
65 years and over | 52.9 | 1.4 | 27.1 | 0.8
Fair or poor health, respondent-assessed
18 years and over | 23.5 | 0.5 | 8.1 | 0.2
18–44 years | 12.6 | 0.6 | 3.7 | 0.2
45–64 years | 28.8 | 0.9 | 10.1 | 0.4
65 years and over | 39.8 | 1.4 | 19.3 | 0.7
Serious psychological distress
18 years and over | 7.2 | 0.3 | 1.5 | 0.1
18–44 years | 6.4 | 0.5 | 1.7 | 0.1
45–64 years | 9.3 | 0.6 | 1.4 | 0.1
65 years and over | 5.0 | 0.6 | 1.1 | 0.2

SE is standard error.

NOTES: Data are for the civilian noninstitutionalized population. Respondents were asked: "During the past 3 months, did you have low back pain?" Respondents were instructed to report pain that lasted a whole day or more and to not report aches or pains that were fleeting or minor. See related Tables 56 and 58. Serious psychological distress is measured by a six-question scale that asks respondents how often they experience six symptoms. See Appendix II, Health status, respondent-assessed; Limitation of activity; Serious psychological distress.

SOURCE: Centers for Disease Control and Prevention, National Center for Health Statistics, National Health Interview Survey.