# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the Office of Analysis and Epidemiology, National Center for Health Statistics (NCHS), under the direction of Amy B. Bernstein, Diane M. Makuc, and Linda T. Bilheimer.

Production of Health, United States, 2006 , highlights, trend tables, and appendixes was managed by Amy B. Bernstein, Sheila Franco, and Virginia M. Freid. Trend tables were prepared by Amy B. Bernstein, Alan J. Cohen, Margaret A. Cooke, La-Tonya D. Curl, Catherine R. Duran, Sheila Franco, Virginia M. Freid, Ji-Eun Lee, Andrea P. MacKay, Livia Navon, Patricia N. Pastor, Mitchell B. Pierre, Jr., Rebecca A. Placek, Laura A. Pratt, Cynthia A. Reuben, and Henry Xia, with assistance from Zahiyah J. Hines, Anita L. Powell, and Ilene B. Rosen. Appendix II tables and the index were assembled by Anita L. Powell. Production planning and coordination of trend tables were managed by Rebecca A. Placek. Administrative and word processing assistance were provided by Lillie C. Featherstone, Lamont Henderson, and Rhonda Robinson.

Production of the Chartbook on Trends in the Health of Americans was managed by Virginia M. Freid. Data and analysis for specific charts were provided by Amy B. Bernstein, Margaret A. Cooke, Sheila Franco, Virginia M. Freid, Deborah D. Ingram, Ji-Eun Lee, Rebecca L. Middendorf, Patricia N. Pastor, and Cynthia A. Reuben. Graphs were drafted by La-Tonya D. Curl and data tables were prepared by Rebecca A. Placek. Technical assistance and programming were provided by Alan J. Cohen, Catherine R. Duran, Livia Navon, Mitchell B. Pierre, Jr., and Henry Xia.

Publications management and editorial review were provided by Demarius V. Miller, Office of Information Services, Information Design and Publishing Staff. Oversight review for publications and electronic products was provided by Margot A. Palmer, Acting Director, Office of Information Services. The designer was Sarah Hinkle, CDC/CoCHIS/NCHM/Division of Creative Services; production was done by Jacqueline M. Davis and Zung T. Le, CDC/CoCHIS/NCHM/Division of Creative Services; and printing was managed by Patricia L. Wilson, CDC/OCOO/MASO.

Electronic access through the NCHS Internet site and CD-ROM was provided by Christine J. Brown, Jacqueline M. Davis, Zung T. Le, Demarius V. Miller, Sharon L. Ramirez, and Patricia L. Wilson.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Catharine W. Burt, Carol J. DeFrances, Marni J. Hall, Esther Hing, Lola Jean Kozak, Karen L. Lipkind, Eric Nawar, Maria F. Owings, William Pearson, Michelle Podgornik, Robert Pokras, Robin E. Remsburg, Susan M. Schappert, and Genevieve W. Strahan; Division of Health Examination Statistics: Lisa Broitman, Margaret D. Carroll, Bruce Dye, Rosemarie Hirsch, Clifford L. Johnson, Ryne Paulose, and Susan E. Schober; Division of Health Interview Statistics: Patricia F. Adams, Veronica E. Benson, Barbara Bloom, Viona I. Brown, Margaret Lethbridge-Cejku, Pei-Lu Chiu, Robin A. Cohen, Richard H. Coles, Marcie Cynamon, Achintya Dey, Cathy C. Hao, Kristina Kotulak-Hays, Susan S. Jack, Jane B. Page, Eve Powell-Griner, Jeannine Schiller, Charlotte A. Schoenborn, Mira L. Shanks, and Luong Tonthat; Division of Vital Statistics: Robert N. Anderson, Elizabeth Arias, Thomas D. Dunn, Donna L. Hoyert, Joyce A. Martin, Kenneth D. Kochanek, T.J. Mathews, Arialdi M. Minino, Sherry L. Murphy, and Stephanie J. Ventura; Office of Analysis and Epidemiology: Lois Fingerhut, Richard F. Gillum, Deborah D. Ingram, Patricia A. Knapp, and Rashmi Tandon; Office of International Statistics: Juan Rafael Albertorio-Diaz and Francis C. Notzon; Office of the Director: Donna Pickett; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were also provided by the following organizations of the Centers for Disease Control and Prevention: Epidemiology Program Office: Samuel L. Groseclose and Patsy A. Hall; National Center for Chronic Disease Prevention and Health Promotion: Laura Kann, Steve Kinchen, Shari L. Shanklin, and Lilo Strauss; National Center for HIV, STD, and TB Prevention: Chandra M. Pendergraft; National Immunization Program: Natalie J. Darling; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: David Kashihara, Steven Machlin, and Marc W. Zodet; Centers for Medicare & Medicaid Services: Cathy A. Cowan, Cherron A. Cox, Frank Eppig, Denise F. Franz, David A. Gibson, Deborah W. Kidd, and Anna Long; National Institutes of Health: Catherine C. Cowie, Lynn A. G. Ries, and Douglas Rugh; Substance Abuse and Mental Health Services Administration: Daniel Foley; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor; Bureau of Justice Statistics: Allen Beck; Bureau of Labor Statistics: Stella Cromartie, Kay Ford, Daniel Ginsburg, John Stinson, and Peggy Suarez; Department of Veterans Affairs: William Kloiber, Dat Tran, and Henry Caplan; American Association of Colleges of Pharmacy: Jennifer M. Patton; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Dental Education Association: Richard Weaver; Association of Schools of Public Health: Mah-Sere K. Sow; Cowles Research Group: C. McKeen Cowles; and InterStudy: Tracy Coats.