# Appendices

Appendix I - Data Sources

Appendix II - Definitions and Methods

Appendix III - Additional Data Years Available