# Appendix III - Additional Data Years Available

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus05tables/)

For trend tables spanning long periods, only selected data years are shown to highlight major trends. Additional years of data are available for some of the tables in electronic spreadsheets available through the Internet and on CD-ROM.

To access spreadsheet files on the Internet, go to the Health, United States Web site at www.cdc.gov/nchs/hus.htm, scroll down to "Spreadsheet Files," and click on 2005 Edition.

Downloadable spreadsheet files for trend tables, many of which include more data years than are shown in the printed report, are available in Excel. Standard errors are included in spreadsheet files for trend tables based on the National Health Interview Survey (NHIS), National Health and Nutrition Examination Survey (NHANES), and National Survey of Family Growth (NSFG).

Spreadsheet files in Excel are also available on a CD-ROM. A limited supply of CD-ROMs are available from the National Center for Health Statistics upon request, while supplies last, or CD-ROMs may be purchased from the Government Printing Office.

Table number | Table topic | Additional data years available
2 | Poverty | 1986–89, 1991–94, 1996–99
3 | Fertility rates and birth rates | 1981–84, 1986–89, 1991–94, 1996
4 | Live births | 1972–74, 1976–79, 1981–84, 1986–89, 1991–94, 1996–99, 2001
5 | Twin births | 1972–74, 1976–79, 1981–84, 1986–89, 1991–94, 1996, 1998
7 | Prenatal care | 1981–84, 1986–89, 1991–94, 1996, 1998
9 | Teenage childbearing | 1981–84, 1986–89, 1991–94, 1996–97
10 | Nonmarital childbearing | 1981–84, 1986–89, 1991–94, 1996–97
11 | Maternal education | 1981–84, 1986–89, 1991–94, 1996–97
12 | Maternal smoking | 1991–94, 1996–97
13 | Low birthweight | 1981–84, 1986–89, 1991–94, 1996–97
14 | Low birthweight | 1991–94, 1996–97
15 | Low birthweight | 1972–74
16 | Abortions | 1981–84, 1986–89, 1991–94, 1996
19 | Infant mortality rates | 1996–97
20 | Infant mortality rates | 1984–89, 1991, 1996–2000
21 | Infant mortality rates | 1984, 1986–89, 1991, 1996–97, 1996–98, 1999–2001
22 | Infant mortality rates | 1981–84, 1986–89, 1991–94
27 | Life expectancy | 1975, 1981–84, 1986–89
29 | Age-adjusted death rates for selected causes | 1981–89, 1991–94, 1996–99
30 | Years of potential life lost | 1991–94, 1996–99; Crude 1999–2001
35 | Death rates for all causes | 1981–89, 1991–94, 1996–97
36 | Diseases of heart | 1981–89, 1991–99
37 | Cerebrovascular diseases | 1981–89, 1991–99
38 | Malignant neoplasms | 1981–89, 1991–99
39 | Malignant neoplasms of trachea, bronchus, and lung | 1981–89, 1991–99
40 | Malignant neoplasm of breast | 1981–89, 1991–99
41 | Chronic lower respiratory diseases | 1981–89, 1991–94, 1996–98
42 | Human immunodeficiency virus (HIV) disease | 1988–89, 1991–94, 1996–98
43 | Maternal mortality | 1981–89, 1991–94, 1996–98
44 | Motor vehicle–related injuries | 1981–89, 1991–99
45 | Homicide | 1981–89, 1991–99
46 | Suicide | 1981–89, 1991–99
47 | Firearm-related injuries | 1981–89, 1991–94, 1996–99
48 | Occupational diseases | 1981–84, 1986–89, 1991–94, 1996–98
49 | Occupational injury deaths | 1993–94, 1996
51 | Notifiable diseases | 1985, 1988–89, 1991–99
53 | Cancer incidence rates | 1991–94
56 | Respiratory conditions | 1998–2001
57 | Severe headache or migraine, low back pain, and neck pain | 1998–2001
58 | Limitation of activity | 1999–2000
59 | Vision and hearing limitations | 1998–99, 2001
60 | Respondent-assessed health status | 1998
63 | Cigarette smoking | 1983, 1987–88, 1991–94, 1997
64 | Cigarette smoking | 1983, 1987–88, 1991–94, 1997
65 | Cigarette smoking | 1993–95, 1994–97
67 | Use of selected substances | 1981–89, 1992–94, 1996–99
68 | Alcohol consumption | 1998–2001
72 | Leisure-time physical activity | 1991–2001
75 | Health care visits | 1998–2001
76 | Influenza and pneumococcal vaccination | 1991, 1993–94, 1997–2001
77 | Vaccinations | 1996–97
80 | No usual source of health care | 1995–96, 1997–98
81 | Emergency department visits for children | 1998–2001
83 | Emergency department visits for adults | 1998–99, 2001
84 | Dental visits | 1998–2001
85 | Untreated dental caries | 1999–2000
86 | Mammography | 1993
88 | Ambulatory care visits | 1997–2000
89 | Injury-related visits | 1997–98, 1999–2000, 2000–01, 2001–02
90 | Ambulatory care visits | 1980, 1997–99, 2001–02
91 | Prescription drug use | 1999–2000
93 | Additions to mental health organizations | 1992, 1998
96 | Discharges | 1998–2001
97 | Discharges | 1991–94, 1996–97, 1999
98 | Rates of discharges | 1995–99, 2001–02
99 | Discharges | 1995–99, 2001–02
100 | Inpatient procedures | 1991–92, 2001–02
101 | Hospital admissions | 1985, 1991–94, 1996–99
102 | Nursing home residents | 1997
103 | Nursing home residents | 1997
106 | Physicians | 1970, 1980, 1987, 1989–90, 1992–94, 1996–98
107 | Primary care doctors of medicine | 1994, 1996–99
109 | Health professions schools | 1996, 1998–99, 2001
110 | Total enrollment of minorities in schools | 2000–01
111 | Enrollment of women in schools | 2000–01, 2001–02
112 | Hospitals | 1985, 1991–94, 1996–99
113 | Mental health organizations | 1992
114 | Community hospital beds | 1985, 1988–89, 1995–2001
115 | Occupancy rates | 1985, 1988–89, 1995–99, 2001–02
116 | Nursing homes | 1996–99, 2001–02
117 | Medicare–certified providers and suppliers | 1970, 1998
124 | Expenditures for health care | 1996, 1998–99, 2001
125 | Sources of payment for health care | 1996, 1998–99, 2001
128 | Employers' costs and health insurance | 1992–93, 1995, 1997, 1999
129 | Hospital expenses | 1975, 1985, 1991–94, 1996–98, 2001
130 | Nursing home average monthly charges | All: 1995, 1997; 1977, 1997
131 | Mental health expenditures | 1992
132 | Private health insurance | 1994, 1996
133 | Medicaid coverage | 1994, 1996
134 | No health insurance coverage | 1994, 1996
135 | Health care coverage | 1984, 1994, 1996–98
136 | Health maintenance organization | 1997, 1999, 2001
137 | Health maintenance organizations | 1984, 1986–87, 1989, 1991–94, 1996–97, 2001–02
139 | Medicare | 1999
141 | Medicare | 1993–2000
142 | Medicaid | 1975, 1985–89, 1991–94, 1996
143 | Medicaid | 1975, 1985–89, 1991–94, 1996
144 | Department of Veterans Affairs | 1985, 1988–89, 1991–94, 1996–98
145 | Personal health care per capita expenditures | 1992–93
146 | Hospital care per capita expenditures | 1992–93
147 | Physician services per capita expenditures | 1992–93
148 | Nursing home care per capita expenditures | 1992–93
149 | Drugs per capita expenditures | 1992–93
153 | Medicare | 1995–2001
154 | Medicaid | 1998, 2000
155 | Health maintenance organizations | 1994, 1996–97, 1999, 2001–02