# Executive Summary

Health, United States, 2005, is the 29th annual report on the health status of the Nation prepared by the Secretary of the Department of Health and Human Services for the President and Congress. In a chartbook and 156 detailed tables, it provides an annual picture of health for the entire Nation. Trends are presented in health status and health care utilization, resources, and expenditures.

For those entrusted with safeguarding the Nation's health, monitoring the health of the American people is an essential step in making sound health policy and setting priorities for research and programs. Measures of the population's health provide essential information for assessing how the Nation's resources should be directed to improve the health of the population. Examination of emerging trends identifies diseases, conditions, and risk factors that warrant study and intervention. Health, United States presents trends and current information on measures and determinants of the Nation's health. It also identifies differences in health and health care among people of differing races and ethnicities, genders, education and income levels, and geographic locations, and it shows whether these differences are narrowing or increasing. Given the increasing diversity of the Nation and the continuing changes in the health care infrastructure, this is a challenging task, but it is a critically important undertaking.

## Overall Health of the Nation

The health of the Nation continues to improve overall, in part because of the significant resources devoted to public health programs, research, health care, and health education. Over the past century many diseases have been controlled or their morbidity and mortality substantially reduced. Notable achievements in public health have included the control of infectious diseases such as typhoid and cholera through decontamination of water; implementation of widespread vaccination programs to eradicate or contain polio, diphtheria, pertussis, and measles; fluoridation of water to drastically reduce the prevalence of dental caries; and improvements in motor vehicle safety through vehicle redesign and efforts to increase use of seatbelts and motorcycle helmets (1). A sharp decline in deaths from cardiovascular disease is a major public health achievement that resulted in large part from public education campaigns emphasizing a healthy lifestyle and increased use of cholesterol and hypertension-lowering medications (2). Yet even as progress is made in improving both the quantity and quality of life, increased longevity is accompanied by increased prevalence of chronic conditions and their associated pain and disability. In recent years, progress in some arenas—declines in infant and cause-specific mortality, morbidity from chronic conditions, reduction in prevalence of risk factors including smoking and lack of exercise—has not been as rapid as in earlier years or trends have been moving in the wrong direction. It is equally important to keep in mind that these improvements have not been equally distributed by income, race, ethnicity, education, and geography.

### Health Status and Its Determinants

Life expectancy in the United States continues to show a long-term upward trend, although the most dramatic increases were in the early part of the 20th century. In 2003 American men could expect to live 3 years longer, and women more than 1 year longer, than they did in 1990. Infant mortality and mortality from heart disease, stroke, and cancer continued to decline in recent years (figures 26,27,29, andtables 22,27, and29). In 2002 the infant mortality rate in the United States increased for the first time since 1958; preliminary data indicate a small, but not statistically significant, decline in 2003 (3,4).

Childhood infectious diseases such as mumps and measles have all but disappeared (table 51), but the prevalence of many chronic diseases is increasing in part associated with increased longevity and aging of the population (figure 1 and table 1). In 1999–2002, more than 9 percent of persons 20 years of age and over and about one-fifth of adults 60 years and over had diabetes, including those with diabetes previously diagnosed by a physician and those with undiagnosed diabetes determined by results of a fasting blood sugar test (table 55). A substantial proportion of the population also experiences discomfort from conditions such as arthritis, headache, and back pain, which can affect quality of life. In 2003, 15 percent of adults suffered with severe headache or migraine during the past 3 months (figure 17 and table 57). Nearly twice as many adults reported low back pain (figure 17 and table 57).

Of particular concern in recent years has been the increase in overweight and obesity, which are risk factors for many chronic diseases and disabilities including heart disease, hypertension, and back pain. The rising number of children and adolescents who are overweight, and the high percentage of Americans who are not physically active (figures 13–15 and tables 72–74) raise additional concerns about Americans' future health (5).

Decreased cigarette smoking among adults is a prime example of a trend that has contributed to overall declines in mortality. However, the rapid drop in cigarette smoking in the two decades following the first Surgeon General's Report in 1964 has slowed in recent years. About 24 percent of men and 19 percent of women were current smokers in 2003 (figure 10 and table 63).

Prevalence of risky behaviors has also improved over time, including the percent of high school students in grades 9–12 who rode with a driver who had been drinking alcohol. This statistic decreased from 40 percent to 30 percent between 1991 and 2003, yet further reductions are certainly necessary (figure 12) (6).

### Health Care Utilization and Resources

People use health care services for many reasons: to treat illnesses, injuries, and health conditions; to prevent or delay future health care problems; to reduce pain and increase quality of life; and to obtain information about their health status and prognoses. The study of trends in health care utilization provides important information on these phenomena and spotlights areas that warrant further study. Utilization trends may also be used to project future health care needs and expenditures, as well as training and supply needs.

Admissions to hospitals and length of stay declined substantially in the 1980s and 1990s, but these declines appear to be leveling off (tables 97–99). The diagnoses recorded on inpatient hospital stays are changing, as are the procedures performed on inpatients (table 100). Hospitalizations for procedures that can be performed on an outpatient basis, such as lens extractions and knee arthroscopies, have all but disappeared from inpatient settings. Instead, inpatient care is becoming more intensive and complex, with more procedures such as insertions of cardiac stents and hip replacements being performed, particularly on older persons (figure 25 and table 100). In addition to changes in the location of services, the types of services being provided have changed. In particular, the number of drugs prescribed or administered during visits to physicians and hospital outpatient departments is increasing (table 92).

Americans are increasingly using many types of preventive or early-detection health services. Since the late 1980s the percentages of older adults who had received pneumococcal and influenza vaccine have increased sharply but remain below desired levels (table 76). The percentage of children 19–35 months of age vaccinated for many childhood infectious diseases is at a high level (81 percent), and the percentage of children receiving varicella (chickenpox) vaccine has increased sharply since it was first recommended in 1996 (table 77). Rates of Pap smears and mammograms have increased since 1987 when national data first became regularly available (figures 21, 22, and tables 86 and 87).

As the nature of health care changes, so do the supply of health providers and the sites where services are provided. Services that historically were provided in inpatient settings are increasingly offered in outpatient settings, and the number of physical therapy providers, comprehensive outpatient rehabilitation facilities, and ambulatory surgical centers certified by the Centers for Medicare & Medicaid Services has increased since the 1980s (table 117). As a result of this shifting in the sites of care, the supply of some other providers or service sites has declined, such as the number of inpatient mental health organizations and the associated number of beds (table 113).

### Expenditures and Health Insurance

The United States spends more on health per capita than any other country, and health spending continues to increase rapidly. Much of this spending is for care that controls or reduces the impact of chronic diseases and conditions affecting an aging population. Prescription drugs and cardiac operations are two notable examples. In 2003 national health care expenditures in the United States totaled $1.7 trillion, a 7.7 percent increase from 2002 (table 119). Since 1995 the average annual rate of increase for prescription drug expenditures was higher than for any other type of health expenditure (table 122), indicating the growing importance of prescription drugs. The source of payment for personal health care varies according to the type of care provided. In 2003, government sources were the primary payers of hospital and nursing home care, paying for about three-fifths of these types of services, while private health insurance paid for almost one-half of physician services and prescription drugs (table 123).

Access to health care is determined by many factors, including the supply of providers and the ability to use and pay for available care. The percent of the population under 65 years of age with no health insurance coverage fluctuated about 16–18 percent between 1994 and 2003 (figure 6 and table 134). The percent of the population with private health insurance decreased between 1999 and 2003 (figure 6 and table 132). This decrease was offset by an increase in Medicaid coverage (table 133), resulting in little change in the percentage uninsured. Employer-sponsored health insurance in particular has been declining in recent years. Between 2001 and 2003 the proportion of the population under 65 years of age with health insurance obtained through the workplace (a current or former employer or union) declined from 67 to 63 percent (table 132).

### Disparities in Risk Factors, Access, and Utilization

Efforts to improve Americans' health in the 21st century will be shaped by important changes in demographics. Ours is a Nation that is growing older and becoming more racially and ethnically diverse. In 2004 nearly one-third of adults and about two-fifths of children were identified as black, Hispanic, Asian, or American Indian or Alaska Native. Fourteen percent of Americans in 2004 identified themselves as Hispanic, 12 percent as black, and 4 percent as Asian (figure 3).

Health, United States, 2005, identifies major disparities in health and health care that exist by socioeconomic status, race, ethnicity, and insurance status. Persons living in poverty are considerably more likely to be in fair or poor health and to have disabling conditions, and less likely to have used many types of health care. In 2003 adults living in poverty were almost twice as likely to report having trouble seeing—even with eyeglasses or contact lenses—as higher income persons (table 59), and were also almost twice as likely to report having had an asthma attack in the past year (table 56). Non-Hispanic black children 3–10 years of age had higher asthma attack prevalence rates than non-Hispanic white or Hispanic children, and this disparity has been increasing in recent years (figure 16).

Large disparities in infant mortality rates remain among racial and ethnic groups (figure 28 and table 19). The gap in life expectancy between the black and white populations has narrowed, but persists (table 27). Disparities in risk factors, access to health care, and morbidity also remain. Hispanic and American Indian persons under 65 years are more likely to be uninsured than those in other racial and ethnic groups (table 134). Obesity, a major risk factor for many chronic diseases, varies by race and ethnicity (tables 73 and 74). In 2003 the rate of recent mammogram screening for white and black women was similar but rates for Asian and Hispanic women remained at a lower level (figure 21 and table 86).

Many aspects of the health of the Nation have improved, but the health of some racial and ethnic groups has improved less than others. The large differences in health status by race and Hispanic origin documented in this report may be explained by factors including socioeconomic status, health practices, psychosocial stress and resources, environmental exposures, discrimination, and access to health care (7). Socioeconomic and cultural differences among racial and ethnic groups in the United States will likely continue to influence future patterns of disease, disability, and health care use.

## Special Feature: Adults 55–64 Years of Age

The population group age 55–64 years is projected to be the fastest growing segment of the adult population over the next decade. In 2004 there were about 29 million persons in this age group. The 55–64 age group is projected to increase by 11 million persons over the 2004–2014 period (figure 30), to 40 million persons by 2014. "Baby boomers" are those born during the post-World War II period, between 1946 and 1964. In 2004 the oldest baby boomers were 55–58 years of age, and just beginning to enter the 55–64 year age group. Many more boomers will age into the group in the next 10 years. In future decades the population age 65 years and over will increase dramatically—yet the population age 55–64 years will not decline because more boomers will replace the ones that age into older age groups. Focusing on this age group may provide insight into program and policy interventions that could improve access and quality of care for Americans age 55–64 years as well as highlight implications for the Medicare program as this large group ages into Medicare and Social Security. This year's Chartbook on Trends in the Health of Americans includes a Special Feature focusing on health care use and expenditures for adults age 55–64 years of age, and determinants of care including employment status, income, health insurance, and risk factors.

People age 55–64 years often have more frequent and more severe health problems than younger people. The prevalence of diabetes, hypertension, heart disease, and other chronic diseases increases with age (tables 55 and 69). There is also evidence that prevalence of some risk factors associated with heart disease—hypertension and obesity—has been increasing among this group while the prevalence of elevated cholesterol has declined (figure 34). Between 1988–94 and 1999–2002, the percent with at least one of these heart disease risk factors increased for men age 55–64 years from 64 to 72 percent and remained steady for women at 73–75 percent. Utilization of prescription drugs for these conditions has increased substantially. Between 1995–96 and 2002–03 the rate of cholesterol-lowering drugs prescribed during physician and hospital outpatient department visits among men 55–64 years of age almost tripled and among women increased more than three-fold (figure 36). Increasing drug utilization overall also has economic implications. The average annual expenses for all prescription drugs and out-of-pocket expenses for drugs increased substantially between 1997 and 2002 for this group (2002 dollars; figure 37).

Americans age 55–64 years are more likely to have health insurance coverage than younger adults age 18–54 (table 134). However as they grow older and begin to develop health problems, they do not have the guarantee of health insurance coverage that Medicare offers to almost all older adults age 65 years and over. Those still employed may delay retirement plans and continue to work in order to maintain health insurance coverage for themselves or their spouses until they reach age 65. In 2002–03 more than one-half of adults 55–64 years of age were employed with 17 percent retired and 12 percent unemployed due to disability (data table for figure 31).

Uninsured 55–64 year-olds may be at risk for high out-of-pocket expenditures, or of delaying or not receiving needed nonurgent care. Persons 55–64 years of age without health insurance were considerably less likely to have health care visits in the past year than persons with private insurance. About one-half of the uninsured 55–64 year-olds saw a general physician (family medicine practitioner, internist, or general practitioner) at least once in the past year compared with 80 percent of those with private insurance (figure 35). When the uninsured 55–64 year-olds do become eligible for Medicare, they may use more health care resources as a result of health care that was delayed at earlier ages (8).

Many Americans age 55–64 years are relatively well off; however certain subgroups including unmarried persons, women, and minorities are at a greater risk of living in poverty, lacking health insurance, and being disabled (data tables for figures 31–33). Among both men and women 55–64 years of age, non-Hispanic black and Hispanic adults were about twice as likely to be living in poverty as non-Hispanic white adults in 2003. Levels of disability reported as a reason for unemployment were also higher among non-Hispanic black men and particularly among non-Hispanic black women age 55–64 years than among other racial and ethnic groups (figure 31). Those without health insurance or adequate income are particularly vulnerable to the financial and physical burdens of disease and disability.

To improve the health of all Americans and to enable policymakers to chart future trends, target resources most effectively, and set program and policy priorities, it is critical that the Nation keep collecting and disseminating reliable and accurate information about all components of health, including current health status, the determinants of health, resources, and outcomes. The following highlights from Health, United States, 2005 With Chartbook on Trends in the Health of Americans summarize the latest findings gathered from across the public and private health care sectors to help the Department of Health and Human Services, the President, and Congress in carrying out this essential mission.

## References

1 Ten great public health achievements—United States, 1900–1999 MMWR 48 12 241 3 1999 Available at www.cdc.gov/mmwr/preview/mmwrhtml/00056796.htm accessed on February 18, 2005.10220250
2 Achievements in Public Health, 1900–1999: Decline in deaths from heart disease and stroke—United States, 1900–1999 MMWR 48 30 649 56 1999 Available at www.cdc.gov/mmwr/preview/mmwrhtml/mm4830a1.htm accessed on June 1, 2005.10488780
3 MacDorman MF, Martin JA, Mathews TJ, Hoyert DL, Ventura SJ. Explaining the 2001–2002 infant mortality increase: Data from the linked birth/infant death data set. National vital statistics reports; vol 53 no 12. Hyattsville, Maryland: National Center for Health Statistics. 2005. Available at www.cdc.gov/nchs/data/nvsr/nvsr53/nvsr53_12.pdf accessed on March 3, 2005.
4 Hoyert DL, Kung H, Smith BL. Deaths: Preliminary data for 2003. National vital statistics reports; vol 53 no 15. Hyattsville, Maryland. National Center for Health Statistics. 2005. Available at www.cdc.gov/nchs/data/nvsr/nvsr53/nvsr53_15.pdf accessed on March 3, 2005.
5 Flegal KM, Carroll MD, Ogden CL, et al. Prevalence and trends in obesity among U.S. adults, 1999–2000. JAMA. 2002;288(14):1723-7. [pmid: 12365955].
6 Centers for Disease Control and Prevention, Surveillance summaries Youth risk behavior surveillance—United States, 2003 MMWR 53 SS02 1 96 2004 Available at www.cdc.gov/mmwr/preview/mmwrhtml/ss5302a1.htm accessed on March 3, 2005.
7 Williams DR, Rucker TD. Understanding and addressing racial disparities in health care. Health Care Financing Review. 2000;21(4):75-90. [pmid: 11481746].
8 McWilliams JM, Zaslavsky AM, Meara E, Ayanian JZ. Impact of Medicare coverage on basic clinical services for previously uninsured adults. JAMA. 2003;290(6):757-64. [pmid: 12915428].