# Highlights

Health, United States, 2004 is the 28th report on the health status of the Nation. It assesses the Nation’s health by presenting trends and current information on selected determinants and measures of health status in a chartbook followed by 153 trend tables. The 2004 Chartbook on Trends in the Health of Americans features a section on use of drugs, which are assuming an ever-increasing role in health care in preventing and curing diseases, reducing complications, controlling symptoms, and improving quality and length of life. The trend tables that follow the chartbook are organized around four major subject areas: health status and determinants, health care utilization, health care resources, and health care expenditures. Highlights of the featured topic, drugs, follow other major findings from the report.

## Health Status and Determinants

### Population characteristics

Important changes in the U.S. population will shape future efforts to improve health and health care. Two major changes in the demographic characteristics of the U.S. population are the increasing racial and ethnic diversity of the Nation and the growth of the older population.

The racial and ethnic composition of the Nation has changed over time. The Hispanic population and the Asian and Pacific Islander population have grown more rapidly than other racial and ethnic groups in recent decades. In 2002, 13 percent of the U.S. population identified themselves as Hispanic and 4 percent as Asian or Pacific Islander (table 1).

From 1950 to 2000 the proportion of the population age 75 years and over rose from 3 to 6 percent. By 2050 it is projected that 12 percent, or about one in eight Americans, will be 75 years of age or over (figure 2).

In 2002 the overall percent of Americans living in poverty was 12.1 percent, up from 11.7 percent in 2001 and 11.3 percent in 2000, the first increase in the poverty rate since 1993. In 2002 more than one-half of black and Hispanic children under 18 years and more than one-half of the black and Hispanic population age 65 years and over were either poor or near poor (figures 4 and 5 and table 2).

### Fertility

Birth rates for teens continued their steady decline while birth rates for women 35–44 years of age increased in 2002.

The birth rate for teenagers declined for the 11th consecutive year in 2002, to 43.0 births per 1,000 women aged 15–19 years, the lowest rate in more than six decades. The birth rate for 15–17 year olds in 2002 was 40 percent lower than in 1991, and the birth rate for older teens 18–19 years of age was 23 percent lower than the rate in 1991 (table 3).

In 2002 the fertility rate for Hispanic women (94.4 births per 1,000 Hispanic women 15–44 years) was 64 percent higher than for non-Hispanic white women (57.4 per 1,000) (table 3).

Between 1995 and 2002 the birth rate for unmarried women was relatively stable, about 43–44 births per 1,000 unmarried women ages 15–44 years. The birth rate for unmarried black women declined to 66.2 per 1,000 in 2002, an historic low, and the birth rate for unmarried Hispanic women increased for the fourth year in a row to 87.9 per 1,000 (table 9).

### Health Behaviors and Risk Factors

Health behaviors and risk factors have a significant effect on health outcomes. Cigarette smoking increases the risk of lung cancer, heart disease, emphysema, and other respiratory diseases. Overweight and obesity increase the risk of death and disease as well as the severity of disease. Regular physical activity lessens the risk of disease and enhances physical functioning. Heavy and chronic use of alcohol and use of illicit drugs increase the risk of disease and injuries.

Since 1990 the percent of adults who smoke cigarettes has declined only slightly. In 2002, 25 percent of men and 20 percent of women were smokers. Cigarette smoking by adults is strongly associated with educational attainment. Adults with less than a high school education were three times as likely to smoke as were those with a bachelor’s degree or more education in 2002 (figure 12 and tables 60 and 61).

Between 1997 and 2003 the percent of high school students who reported smoking cigarettes in the past month declined from 36 percent to 22 percent, reversing an upward trend that began in the early 1990s. Despite the declines in cigarette smoking rates among high school students, 26 percent of high school students in grade 12 were current smokers in 2003, and 13 percent smoked cigarettes on 20 or more days in the past month (figures 12 and 13).

Cigarette smoking during pregnancy is a risk factor for poor birth outcomes such as low birthweight and infant death. In 2002 the proportion of mothers who smoked cigarettes during pregnancy declined to 11 percent, down from 20 percent in 1989. In 2002 the smoking rate during pregnancy for mothers ages 18–19 years (18 percent) remained higher than that for mothers of other ages (figure 12 and table 11).

Low birthweight is associated with elevated risk of death and disability in infants. In 2002 the rate of low birthweight (infants weighing less than 2,500 grams at birth) increased to 7.8 percent overall, up from 7.0 percent in 1990 (table 12).

In 2003, one-third of high school students, about the same as in 2001, did not engage in the recommended amounts of moderate or vigorous physical activity. The percent reporting an insufficient amount of physical activity was higher for female than for male high school students (figure 14).

In 2002 the percent of adults 18 years of age and over who were inactive during their leisure time was higher for women than men and increased sharply with age. Among adults 18–44 years of age, 30 percent of men and 35 percent of women were inactive during leisure time (figure 15).

The prevalence of overweight and obesity among adults 20–74 years of age increased from 47 percent in 1976–80 to 65 percent in 1999–2002. During this period the prevalence of obesity among adults 20–74 years of age increased from 15 to 31 percent (percents are age adjusted) (figure 16 and table 69).

The prevalence of obesity among adults varies by race and ethnicity. In 1999–2002, 50 percent of non-Hispanic black women 20–74 years of age were obese, compared with 39 percent of women of Mexican origin and 31 percent of non-Hispanic white women (percents are age adjusted). Obesity among black women increased 60 percent since 1976–80, from 31 percent to 50 percent (figure 17 and table 69).

Between 1976–80 and 1999–2002 the prevalence of overweight among children 6–11 years of age more than doubled from 7 to 16 percent and the prevalence of overweight among adolescents 12–19 years of age more than tripled from 5 to 16 percent (figure 16 and table 70).

In 2002 among current drinkers age 18 years and over, 41 percent of men and 20 percent of women reported drinking five or more alcoholic drinks on at least 1 day in the past year (age adjusted). This level of alcohol consumption was most common among young adults 18–24 years of age (table 66).

In 2002 the prevalence of illicit drug use within the past 30 days among youths 12–17 years of age was almost 12 percent. The percent of youths reporting illicit drug use increased with age, from 4 percent among 12–13 year olds to 11 percent among those age 14–15 years and 20 percent among those 16–17 years in 2002 (table 63).

Between 1991 and 2002 the number of cocaine-related emergency department episodes per 100,000 population tripled for persons 35 years and over, to 79 episodes per 100,000. Males, age 26–34 years, had the highest episode rate, 222 per 100,000 in 2002. The same patient may be involved in multiple drug-related episodes (table 65).

### Morbidity

Limitation of activity due to chronic health conditions, limitations in activities of daily living, and self-assessed (or family member-assessed) health status are summary measures of morbidity presented in this report. Additional measures of morbidity include the incidence and prevalence of specific diseases, injury-related emergency department use, and suicide attempts.

Between 1997 and 2002 limitation of activity due to chronic health conditions was reported for 6–7 percent of children under the age of 18 years. Among preschool children (under 5 years) the chronic conditions most often mentioned were speech problems, asthma, and mental retardation or another developmental problem. Among school-age children (5–11 and 12–17 years), learning disabilities and Attention Deficit Hyperactivity Disorder (ADHD) were the conditions most often mentioned (table 56 and figure 18).

Limitations in handling personal care needs such as bathing (activities of daily living or ADLs) increase sharply with age among the noninstitutionalized population. In 2002, 14 percent of all Medicare beneficiaries 65 years of age and over were limited in at least one of six ADLs. Among noninstitutionalized persons age 65 years and over, about 11 percent had difficulty and received help or supervision with at least one ADL (figure 21).

Mental illness is a significant cause of activity limitation among working-age adults living in the community. In 2000–2002 mental illness was the second most frequently mentioned causal condition for activity limitation among adults 18–44 years of age and the third most frequently mentioned among adults 45–54 years (figure 20).

In 2002 the percent of persons reporting their health status as fair or poor was more than three times as high for persons living below the poverty level as for those with family income more than twice the poverty level (20 percent and 6 percent, age adjusted). Levels of fair or poor health were higher in the South and outside of metropolitan areas (table 57).

New pediatric AIDS cases have been declining steadily since 1994 when U.S. Public Health Service guidelines recommended testing and treatment of pregnant women and neonates to reduce perinatal HIV transmission. The vast majority of pediatric AIDS cases occur through perinatal exposure. In 2003, about 150 new AIDS cases were reported among children under the age of 13 years, compared with more than 700 cases in 1990 (table 52).

In 2002 tuberculosis incidence declined for the 10th consecutive year to 5.4 cases per 100,000 population, down from 10.5 in 1992 and 12.3 in 1980 (table 51).

Untreated chlamydial infections can lead to pelvic inflammatory disease (PID) with potentially serious complications including infertility, chronic pelvic pain, and life-threatening tubal pregnancy. In 2002 the reported rate for chlamydial infection was 297 cases per 100,000 persons. Rates of reported chlamydial infection have been increasing annually since the late 1980s when public programs for screening and treatment of women were first established to avert pelvic inflammatory disease and related complications (table 51).

In 1999–2000 more than 8 percent of persons 20 years of age and over were estimated to have diabetes, including diabetes previously diagnosed by a physician and undiagnosed diabetes based on the results of a fasting blood sugar examination. Diabetes rises sharply with age and is more common among non-Hispanic black and Mexican adults than non-Hispanic white adults (based on age-adjusted rates) (table 55).

Incidence rates for all cancers combined declined in the 1990s for males. Between 1990 and 2000 age-adjusted cancer incidence rates declined on average 1 percent or more per year for black males, non-Hispanic white males, and American Indian or Alaska Native males. Although there was no significant change in cancer incidence for females overall, among non-Hispanic white females and Asian or Pacific Islander females, cancer incidence increased on average 0.4 percent per year between 1990 and 2000, a significant increase (table 53).

The most frequently diagnosed cancer sites in males are prostate, followed by lung and bronchus, and colon and rectum. Cancer incidence at these sites is higher for black males than for males of other racial and ethnic groups. In 2000 age-adjusted cancer incidence rates for black males exceeded those for white males by 66 percent for prostate, 46 percent for lung and bronchus, and 17 percent for colon and rectum (table 53).

Breast cancer is the most frequently diagnosed cancer among females. Breast cancer incidence is higher for non-Hispanic white females than for females in other racial and ethnic groups. In 2000 age-adjusted breast cancer incidence rates for non-Hispanic white females exceeded those for black females by 22 percent, for Asian or Pacific Islander females by 54 percent, and for Hispanic females by 59 percent (table 53).

Injuries accounted for 36 percent of all visits to emergency departments (ED) in 2001–2002. The proportion of ED visits that were injury-related declined with age from 39 percent for children and adults under 45 years of age to 33 percent for persons 45–64 years and 27 percent for those 65 years and over. Males had a higher injury-related visit rate than females overall and for all age groups under 65 years (tables 83 and 84).

Between 1993 and 2003 the percent of high school students who reported attempting suicide (8–9 percent) and whose suicide attempts required medical attention (just under 3 percent) remained fairly constant. Girls were more likely than boys to consider or attempt suicide. However in 2002 adolescent boys (15–19 years of age) were five times as likely to die from suicide as were adolescent girls, in part reflecting their choice of more lethal methods, such as firearms (tables 46 and 59).

The prevalence of serious psychological distress was 3 percent of civilian noninstitutionalized adults 18 years of age and over in 2001–02. Four percent of persons age 45–54 years had serious psychological distress, more than younger and older age groups. Persons living below the poverty line were four times as likely as those above 200 percent of poverty to have serious psychological distress (8 percent compared with 2 percent) (table 58).

### Mortality Trends

Life expectancy and infant mortality are measures often used to gauge the overall health of a population. Life expectancy shows a long-term upward trend. Infant mortality increased in 2002, the first year since 1958 that the rate has not declined or remained unchanged.

In 2002 life expectancy at birth for the total population reached a record high of 77.4 years, up from 75.4 years in 1990 (table 27).

In 2002 the infant mortality rate was 7.0 infant deaths per 1,000 live births, up from 6.8 in 2001. Between 1958 and 2001, the infant mortality rate either decreased or remained level. The rise in infant mortality in 2002 is attributed to an increase in neonatal deaths (within 28 days of birth), particularly deaths of infants within the first week of life (figure 23 and table 22).

Between 1950 and 2002 the age-adjusted death rate for the total population declined 42 percent to 845 deaths per 100,000 population. This reduction was driven largely by declines in mortality from heart disease, stroke, and unintentional injury (figure 25 and table 29).

Mortality from heart disease, the leading cause of death, declined almost 3 percent in 2002, continuing a long-term downward trend. The 2002 age-adjusted death rate for heart disease was 59 percent lower than the rate in 1950 (figure 25 and tables 29 and 31).

Mortality from cancer, the second leading cause of death, decreased more than 1 percent in 2002, continuing the decline that began in 1990. Overall cancer age-adjusted death rates rose from 1960 to 1990 and then reversed direction (figure 25 and tables 29 and 31).

Mortality from stroke, the third leading cause of death, declined almost 3 percent in 2002. Between 1950 and 2002, the age-adjusted death rate for stroke declined 69 percent (figure 25 and tables 29 and 31).

The age-adjusted death rate for chronic lower respiratory diseases (CLRD), the fourth leading cause of death, was 54 percent higher in 2002 than in 1980. The upward trajectory for CLRD death rates is a result of steadily increasing death rates for females, most noticeably for females age 55 years and over (figure 25 and tables 29, 31, and 41).

Mortality from unintentional injuries, the fifth leading cause of death, increased more than 3 percent in 2002. Age-adjusted death rates for unintentional injuries generally declined from 1950 until 1992 and then increased slightly (figure 25 and tables 29 and 31).

### Disparities in Mortality

Despite overall declines in mortality, racial and ethnic disparities in mortality, as well as disparities among persons of different education levels, persist. The gap in life expectancy between the sexes and between the black and white populations has been narrowing.

Large disparities in infant mortality rates among racial and ethnic groups continue. In 2001 infant mortality rates were highest for infants of non-Hispanic black mothers (13.5 deaths per 1,000 live births), American Indian mothers (9.7 per 1,000), and Puerto Rican mothers (8.5 per 1,000); and lowest for infants of mothers of Chinese origin (3.2 per 1,000 live births) and Cuban mothers (4.2 per 1,000) (table 19).

Infant mortality increases as mother’s level of education decreases. In 2001 the mortality rate for infants of mothers with less than 12 years of education was 49 percent higher than for infants of mothers with 13 or more years of education. This disparity was more marked among non-Hispanic white infants, for whom mortality among infants of mothers with less than a high school education was more than twice that for infants of mothers with more than a high school education (table 20).

Between 1990 and 2002 life expectancy at birth increased 2.9 years for males and 1.1 year for females. The difference in life expectancy between males and females narrowed from 7.0 years in 1990 to 5.2 years in 2002 (figure 22 and table 27).

Between 1990 and 2002 mortality from lung cancer declined for men and increased for women. Although these trends reduced the sex differential for this cause of death, the age-adjusted death rate for lung cancer was still 76 percent higher for men than for women in 2002 (table 39).

Since 1990 mortality from chronic lower respiratory diseases remained relatively stable for men while it increased for women. These trends reduced the gap between the sexes for this cause of death. In 1990 the age-adjusted death rate for males was more than 100 percent higher than for females. In 2002 the difference between the rates had been reduced to 43 percent (table 41).

Between 1990 and 2002 life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 1990 life expectancy at birth was 7.0 years longer for the white than for the black population. By 2002 the difference had narrowed to 5.5 years (table 27).

Overall mortality was 31 percent higher for black Americans than for white Americans in 2002 compared with 37 percent higher in 1990. In 2002 age-adjusted death rates for the black population exceeded those for the white population by 41 percent for stroke, 30 percent for heart disease, 25 percent for cancer, and more than 750 percent for HIV disease (table 29).

The 5-year survival rate for black females diagnosed in 1992–99 with breast cancer was 14 percentage points lower than the 5-year survival rate for white females (table 54).

In 2002 breast cancer mortality for black females was 36 percent higher than for white females, compared with less than 15 percent higher in 1990 (based on age-adjusted death rates) (table 40).

Homicide rates among young black males 15–24 years of age and young Hispanic males were about 50 percent lower in 2002 than in 1992 and 1993 when homicide rates peaked for these groups. Despite these downward trends, homicide was still the leading cause of death for young black males and the second leading cause for young Hispanic males in 2002, and homicide rates for young black and Hispanic males remained substantially higher than for young non-Hispanic white males (table 45).

HIV disease mortality peaked in 1995 and then fell sharply with the advent of new drug therapies. However the decline in HIV disease mortality has slowed in recent years. Between 1999 and 2002, age-adjusted death rates for HIV disease declined about 3 percent per year on average for males and were unchanged for females (table 42).

In 2002 the death rate for motor vehicle-related injury for young American Indian males 15–24 years of age was almost 40 percent higher and the suicide rate was almost 60 percent higher than the rates for those causes for young white males. Death rates for the American Indian population are known to be underestimated (tables 44 and 46).

In 2002 age-adjusted death rates for stroke for Asian males ages 45–54 and 55–64 years were about 15 percent higher than for white males of those ages. Since 1990, stroke mortality for Asian males and females ages 45–74 years has generally exceeded that for white males and females of those ages. Death rates for the Asian population are known to be underestimated (table 37).

Death rates vary by educational attainment. In 2002 the age-adjusted death rate for persons 25–64 years of age with fewer than 12 years of education was 2.7 times the rate for persons with 13 or more years of education (table 34).

### Occupational Health

Improvements in workplace safety constitute a major public health achievement in the twentieth century. Despite important accomplishments, preventable injuries and deaths continue to occur.

In 2002 approximately 2.5 million workplace injury and illness cases in the private sector involved days away from work, job transfer, or restriction. The manufacturing and service industries each reported more than 600,000 such cases with incidence rates of 4.1 and 2.2 cases per 100 full-time employees respectively (table 50).

Between 1992 and 2002 the occupational injury death rate decreased 23 percent to 4 deaths per 100,000 employed workers. Mining (including oil and gas extraction), the industry with the highest death rate in 2002 (24 per 100,000), accounted for 2 percent of all occupational injury deaths. The industry accounting for the largest percentage of occupational injury deaths, construction (20 percent), had a death rate of 12 per 100,000 (table 49).

A total of 2,715 pneumoconiosis deaths, for which pneumoconiosis was either the underlying or nonunderlying cause of death, occurred in 2002, compared with 4,151 deaths in 1980. Pneumoconiosis deaths are primarily associated with occupational exposures and can be prevented through effective control of worker exposure to occupational dusts (table 48).

## Health Care Utilization and Health Care Resources

Major changes continue to occur in the delivery of health care in the United States, driven in part by changes in payment policies intended to rein in rising costs and by advances in technology that have allowed more complex treatments to be performed on an outpatient basis. Use of hospital inpatient services overall has decreased, yet inpatient care is becoming more complex with more cardiac procedures performed, especially on older persons. New types of health care providers including ambulatory surgery centers and end-stage renal disease facilities have emerged that provide services previously provided only in hospital settings.

Between 1995 and 2002 the rate of visits to office-based physicians increased from 271 per 100 population to 316 per 100 population (age adjusted). The increase was smaller for persons age 18–44 years than for other age groups (table 83).

In 2002 the hospital emergency department visit rate for black persons was twice the rate for white persons (71 visits compared with 36 visits per 100 persons, age adjusted). Adults 75 years and over had a higher rate of visits to the hospital emergency department than any other age group (61 visits per 100 persons) (table 83).

In 2002, 63 percent of all surgical operations in community hospitals were performed on outpatients, up from 51 percent in 1990 and 16 percent in 1980 (table 98).

In 2002 the hospital discharge rate was 117 discharges per 1,000 population, 23 percent lower than the rate in 1985. Most of the decline in the discharge rate had occurred by 1996. Between 2000 and 2002, the discharge rate increased slightly while average length of stay remained at 4.9 days, 1.7 days shorter than it was in 1985 (data are age adjusted) (table 93).

Between 1991–92 and 2001–02 hospital stays with at least one operation on vessels of the heart performed on persons 75 years of age and over increased from 73 to 124 hospital stays per 10,000 persons (rates are age adjusted) (table 97).

Between 1991–92 and 2001–02 hospital stays with at least one diagnostic ultrasound performed on persons 18 years of age and over decreased substantially from 71 to 32 hospital stays per 10,000 persons (rates are age adjusted) (table 97).

The percent of persons with untreated dental caries has declined for every age group except children 2–5 years of age. In 1999–2000, 26 percent of adults 18–64 years of age had untreated dental caries, following a decline from 48 to 28 percent between 1971–74 and 1988–94 (table 80).

Between 1995 and 2002 allopathic medicine graduates remained stable at nearly 16,000 per year, and osteopathic medicine graduates increased from 1,800 to 2,500 per year (table 106).

Between 1990 and 2002 the number of community hospital beds declined from about 927,000 to 821,000. Community hospital occupancy, estimated at 66 percent in 2002, increased from 62 percent in 1996, after declining from 67 percent in 1990 (table 109).

Between 1990 and 2000 the number of inpatient mental health beds per 100,000 civilian population in the United States declined 31 percent to 77 beds per 100,000 population. The largest decreases were in State and county mental hospitals and private psychiatric hospitals, which each had a decrease of almost 50 percent to 21 beds and 10 beds per 100,000 population, respectively (table 110).

In 2002 there were 6,800 Medicare-certified home health agencies, down from 10,800 in 1997. During this same period, the number of Medicare-certified hospices remained stable at about 2,300 (table 114).

In 2002 there were nearly 1.8 million nursing home beds in facilities certified for use by Medicare and Medicaid beneficiaries. Between 1995 and 2002 nursing home bed occupancy in those facilities was relatively stable, estimated at 82 percent in 2002 (table 113).

### Preventive Health Care

Use of preventive health services helps reduce morbidity and mortality from disease. Use of several different types of preventive services has been increasing. However disparities in use of preventive health care by race and ethnicity, and family income, remain.

The percent of mothers receiving prenatal care in the first trimester of pregnancy has continued to edge upward from 76 percent in 1990 to 84 percent in 2002. Although increases occurred for all racial and ethnic groups, in 2002 the percent of mothers with early prenatal care still varied substantially, from 70 percent for American Indian mothers to 91–92 percent for mothers of Japanese and Cuban origin (figures 8 and 9 and table 6).

In 2002, 78 percent of children 19–35 months of age received the combined vaccination series of four doses of DTaP (diphtheria-tetanus-acellular pertussis) vaccine, three doses of polio vaccine, one dose of MMR (measles-mumps-rubella vaccine), and three doses of Hib (Haemophilus influenzae type b) vaccine. Children living below the poverty threshold were less likely to have received the combined vaccination series than were children living at or above poverty (72 percent compared with 79 percent) (table 72).

In 2002, 66 percent of noninstitutionalized adults 65 years of age and over reported an influenza vaccination within the past year, the same percent as in 1999 and more than double the percent in 1989. Between 1989 and 2002 the percent of older adults ever having received a pneumococcal vaccine increased sharply from 14 percent to 56 percent (figure 10).

Between 1987 and 2000 the percent of women 18 years and over who reported a Pap smear in the past 3 years increased from 74 percent to 81 percent. Among women 25 years and over, in 2000, Pap smear use was lowest among women with less than a high school education and highest among women with at least some college education (70 percent and 88 percent) (table 82).

### Access to Care

Access to care is important for preventive care and prompt treatment of illness and injuries. A major determinant of access to care is health insurance coverage and the generosity of coverage. Indicators of access to health services also include having a usual source of health care and having a recent health care contact.

The percent of the population under 65 years of age with no health insurance coverage (either public or private) fluctuated around 16–17 percent between 1994 and 2002. Among the under 65 population, poor and near poor persons whose family incomes were less than 200 percent of poverty were much more likely than others to be uninsured (figures 6 and 7 and table 131).

The likelihood of being uninsured varies substantially among the States. In 2002 the percent of the population under 65 years of age with no health insurance coverage varied from less than 9 percent in Minnesota to more than 22 percent in Nevada, New Mexico, and Texas (table 153).

In 2002, 11 percent of children under 18 years of age had no health insurance coverage. Between 2000 and 2002 among children with family income just above the poverty level (1–1.5 times poverty), the percent uninsured dropped from 25 to 19 percent. However children with low family income remain substantially more likely than higher-income children to lack coverage (table 131).

Persons of Hispanic origin and American Indians who are under 65 years of age are more likely to have no health insurance coverage than are those in other racial and ethnic groups. In 2002 among the Hispanic-origin population, persons of Mexican origin were the most likely to lack health insurance coverage (37 percent). Non-Hispanic white persons were the least likely to lack coverage (13 percent) (figure 7 and table 131).

In 2002 Hispanic persons were more likely than non-Hispanic white and non-Hispanic black persons to have had no health care visits within the past 12 months (26 percent compared with 14–15 percent, percents are age adjusted) (table 71).

Twelve percent of children under 18 years of age had no health care visit to a doctor or clinic within the past 12 months in 2001–02. Hispanic and non-Hispanic black children were more likely to be without a recent visit than non-Hispanic white children (19 percent and 14 percent compared with 10 percent) (table 74).

Six percent of children under 18 years of age had no usual source of health care in 2001–02. Hispanic children were more likely than other children to be without a usual source of care (9 percent of Hispanic children under 6 years of age and 16 percent of Hispanic children 6–17 years of age were without a usual source of care) (table 75).

Poor children are more likely to have untreated dental caries than children in families with incomes above the poverty level. In 1999–2000, 34 percent of poor children 6–17 years of age had untreated dental caries compared with 13 percent of children in families with incomes 200 percent of the poverty level or greater (table 80).

Twenty-eight percent of young children under 6 years of age had an emergency department (ED) visit within the past 12 months in 2002. Young children with Medicaid coverage were more likely than those with private coverage or the uninsured to have had an ED visit within the past 12 months (38 percent compared with 22–25 percent) (table 76).

Working-age males 18–64 years of age were nearly twice as likely as working-age females to have no usual source of health care in 2001–02 (21 percent of males and 11 percent of females, percents are age adjusted (table 77).

In 2002, 63 percent of working-age adults 18–64 years of age had a dental visit in the past year. Less than one-half of poor and near poor working-age adults (persons with family incomes of less than twice the poverty level) had a dental visit in the past year compared with 69 percent of nonpoor working-age adults (with family incomes of at least twice the poverty level) (table 79).

Use of hospital inpatient care is greater among the poor than among the nonpoor whose family income is at least twice the poverty level. In 2002 among persons under 65 years of age, the hospital discharge rate for the poor was nearly twice the rate for nonpoor (158 and 83 per 1,000 population). Among those under 65 years of age, average length of stay was 1.3 days longer for poor than for nonpoor persons (4.7 and 3.4 days, data are age adjusted) (table 92).

## Health Care Expenditures

After 25 years of double-digit annual growth in national health expenditures, the rate of growth slowed during the 1990s. At the end of the decade the rate of growth started edging up again. Since the millennium, the rate has accelerated with no indication of a slowdown. The United States continues to spend more on health than any other industrialized country.

In 2002 national health care expenditures in the United States totaled more than $1.5 trillion, a 9.3 percent increase, compared with 8.5 percent in 2001 and 7.1 percent in 2000. In the mid-1990s annual growth had slowed somewhat, following an average annual growth rate of 11 percent during the 1980s (table 116).

The United States spends a larger share of the gross domestic product (GDP) on health than does any other major industrialized country. In 2001 the United States devoted 14 percent of the GDP to health compared with 11 percent each in Germany and Switzerland and nearly 10 percent in Canada and France, countries with the next highest shares (table 115).

In 2002 national health expenditures grew 9.3 percent, compared with 3.6 percent growth in the gross domestic product (GDP). Health expenditures as a percent of the GDP increased to 14.9 percent in 2002, up from 14.1 percent in 2001, and 13.2–13.4 percent between 1995 and 2000 (table 116).

In 2003 the rate of increase in the medical care component of the Consumer Price Index (CPI) was 4.0 percent, continuing to outpace overall inflation (2.3 percent). The CPI for hospital services showed the greatest price increase (7.4 percent) compared with other components of medical care (table 117).

### Expenditures by Type of Care and Source of Funds

During the last few years expenditures for prescription drugs have grown at a faster rate than any other type of health expenditure. Hospital care, however, continues to account for the largest share of health care spending.

Expenditures for hospital care accounted for 31 percent of all national health expenditures in 2002. Physician services accounted for 22 percent of the total in 2002, prescription drugs for 11 percent, and nursing home care for 7 percent (table 118).

Between 2000 and 2002 community hospital expenses increased at an average annual rate of 8 percent compared with a 5-percent increase between 1995–2000 (table 125).

Between 1995 and 2002 the average annual rate of increase for prescription drug expenditures was 15 percent, higher than for any other type of health expenditure (table 118).

In 2001 and 2002 prescription drug expenditures increased 15–16 percent. Prescription drugs posted a 5-percent rate of price increase in the Consumer Price Index in 2001 and 2002 and a 3-percent increase in 2003 (tables 117 and 118).

In 2002, 48 percent of prescription drug expenditures were paid by private health insurance (up from 24 percent in 1990), 30 percent by out-of-pocket payments (down from 59 percent in 1990), and 18 percent by Medicaid. Although Medicare is the federal program that funds health care for persons age 65 years and over, and older Americans are the highest per capita consumers of prescription drugs, Medicare paid less than 2 percent of prescription drug expenses in 2002 (table 119).

In 2000, 88 percent of persons age 65 years and over in the civilian noninstitutionalized population had a prescribed medicine expense compared with 59 percent of younger people. Women 65 years of age and over averaged $731 out-of-pocket for prescribed medicine compared with $467 for men in 2000. Among those under 65 years of age, out-of-pocket expenses averaged $218 for women and $175 for men in 2000 (table 120).

In 2000, 96 percent of persons age 65 years and over in the civilian noninstitutionalized population reported medical expenses averaging about $6,100 per person with expense. Eighteen percent of expenses were paid out-of-pocket, 15 percent by private insurance, and 65 percent by public programs (mainly Medicare and Medicaid) (tables 120 and 121).

The burden of out-of-pocket expenses for health care varies considerably by age. In 2000 about one-third of persons 65 years of age and over with health care expenses paid $1,000 or more out-of-pocket and approximately an additional one-fifth incurred expenses of $500 to $1,000. One-fifth of adults 18–44 years of age with health care expenses paid at least $500 out-of-pocket in 2000 (table 122).

In 2002, 34 percent of personal health care expenditures were paid by the Federal Government and 11 percent by State and local government; private health insurance paid 36 percent and consumers paid 16 percent out-of-pocket (table 119).

In 2002 the major sources of funds for hospital care were Medicare (31 percent) and private health insurance (34 percent). Physician services were also primarily funded by private health insurance (49 percent) and Medicare (20 percent). In contrast, nursing home care was financed primarily by Medicaid (49 percent) and out-of-pocket payments (25 percent). The Medicare share of nursing home expenditures has risen from 3 percent in 1990 to 13 percent in 2002 (table 119).

In 2003 Federal expenditures for HIV-related activities grew to $16.7 billion, an 11-percent increase compared with a 6-percent increase in 2002. Of the total Federal HIV-related spending in 2003, 61 percent was for medical care, 17 percent for research, 12 percent for education and prevention, and 10 percent for cash assistance (table 128).

### Publicly Funded Health Programs

The two major publicly funded health programs are Medicare and Medicaid. Medicare is funded through the Federal Government and covers the health care of persons 65 years of age and over and disabled persons. Medicaid is jointly funded by the Federal and State Governments to provide health care for certain groups of low-income persons and, in recent years, has expanded to cover a greater proportion of the low-income population—particularly low-income children. Medicaid benefits and eligibility vary by State.

In 2002 the Medicare program had 41 million enrollees and expenditures of $266 billion (table 136).

In 2002 hospital insurance (HI) accounted for 57 percent of Medicare expenditures. Expenditures for home health agency care continued to hover around 3 percent of HI expenditures, down from 14 percent in 1995 (table 136).

In 2002 supplementary medical insurance (SMI) accounted for 43 percent of Medicare expenditures. Sixteen percent of SMI expenditures in 2002 were payments to managed care organizations, down from 20–22 percent in 1998–2000. Nearly one-half of the $96 billion SMI paid for fee-for-service utilization in 2002 went to physicians under the physician fee schedule (table 136).

Of the 33.9 million Medicare enrollees in the fee-for-service program in 2001, 11 percent were 85 years of age and over and 15 percent were under 65 years of age. Among fee-for-service Medicare enrollees age 65 years and over, payments in 2001 increased with age of enrollee from an average of $4,400 per year per enrollee for those age 65–74 years to $8,500 for those 85 years and over (table 137).

In 2000, 80 percent of Medicare beneficiaries were non-Hispanic white, 9 percent were non-Hispanic black, and 7 percent were Hispanic. Some 22–23 percent of Hispanic and non-Hispanic black beneficiaries were persons under 65 years of age entitled to Medicare through disability, compared with 12 percent of non-Hispanic white beneficiaries (table 138).

In 2001 Medicare payments per fee-for-service enrollee varied by State, ranging from less than $4,400 in Hawaii, South Dakota, and New Mexico to more than $6,800 in New Jersey, the District of Columbia, New York, Maryland, and Louisiana (table 150).

In 2001 Medicaid vendor payments totaled $186 billion for 46 million recipients (table 139).

In 2002 Medicaid enrollment increased to 11.8 percent of the noninstitutionalized population under 65 years of age, up from 10.3 percent in 2001. In 2002 among children less than 18 years of age, 24.5 percent were covered by Medicaid, a 3.3 percentage point increase over the previous year (table 130).

In 2001 children under the age of 21 years accounted for 46 percent of Medicaid recipients but only 16 percent of expenditures. Aged, blind, and disabled persons accounted for nearly one-quarter of recipients and nearly 70 percent of expenditures (table 139).

In 2001, 20 percent of Medicaid payments went to nursing facilities, 14 percent to inpatient general hospitals, 16 percent to capitated payment services, and 13 percent to prescribed drugs (table 140).

In 2001 Medicaid payments per recipient varied by State from less than $3,000 in California, Tennessee, Georgia, and Washington to more than $7,000 in New York and New Hampshire. On average payments per recipient were lower in the Southeast, Southwest, and Far West States than in the New England and Mideast States (table 151).

In 2003 spending on health care by the Department of Veterans Affairs was $26 billion, an increase of 11 percent over the previous year. Forty-one percent of inpatients and 33 percent of outpatients were low-income veterans without a service-connected disability (table 141).

### Health Insurance

Seventy percent of the population under 65 years of age has private health insurance, most of which is obtained through the workplace. In private industry, about 6 percent of employees’ total compensation is devoted to health insurance. Most health insurance is now provided through some form of managed care organization, including health maintenance organizations (HMOs), preferred provider organizations (PPOs), and point-of-service plans (POSs). One-quarter of all persons in the United States were enrolled in HMOs in 2002. HMO enrollment peaked in 1999 and has declined slowly since then.

In 2002 the age-adjusted proportion of the population under 65 years of age with private health insurance declined to 70 percent from 72 percent in 2001. Between 1995 and 2001 the proportion had fluctuated between 71 and 73 percent after declining from 77 percent in 1984. Ninety-four percent of private coverage was obtained through the workplace (a current or former employer or union) in 2002 (figure 6 and table 129).

In 2003 private employers’ health insurance costs per employee-hour worked were $1.41, up from $1.28–1.29 in 2001–02. Among private employers the share of total compensation devoted to health insurance was 5.9–6.3 percent in 2001–03 (table 124).

Enrollment in HMOs totaled 72 million persons or one-quarter of the U.S. population in 2003. HMO enrollment varied from 17–20 percent in the South and Midwest to 32–36 percent in the Northeast and West. HMO enrollment increased steadily through 1999 but declined more than 9 million by 2003. Between 1999 and 2003 the number of HMO plans decreased from 643 to 454 plans (table 134).

In 2002, 25–27 percent of children under 18 years of age and adults age 18–44 and 45–64 years had health insurance coverage through a private HMO. Eleven percent of children had coverage through a Medicaid HMO while 2–3 percent of adults under 65 years of age had this coverage (table 133).

### State Health Expenditures

Total personal health care per capita expenditures and its components vary substantially among the States. State expenditures are affected by factors such as population age structure and health, payment rates, and supply of services.

Personal health care per capita expenditures averaged $3,800 in 1998, but varied among the States from $2,700 in Utah to $4,800 in Massachusetts. Higher expenditures were clustered in the New England and Mideast States, with lower per capita expenditures in the Rocky Mountain, Southwest, and Far West States (table 142).

The components of personal health care expenditures vary significantly by State. Hospital care per capita expenditures in 1998 ranged from $1,016 in Utah to $1,807 in Massachusetts. Physician and other professional services per capita expenditures varied from $763 in Utah to $1,347 in Minnesota. Per capita expenditures for nursing home care ranged from $90 in Alaska to $860 in Connecticut (tables 143–145).

Twenty-one percent of all personal health care expenditures were paid by Medicare in 1998, up from 17 percent in 1991. The Medicare share of State health expenditures in 1998 varied from 9 percent in Alaska to 25–26 percent in Pennsylvania, Mississippi, and Louisiana, and 28 percent in Florida (table 147).

The share of personal health care expenditures paid by Medicaid increased from 13 percent in 1991 to 16 percent in 1995 through 1998. The Medicaid share of personal health care expenditures in 1998 ranged from less than 10 percent in Nevada and Virginia, to 21–22 percent in the District of Columbia, Maine, and Rhode Island, and 32 percent in New York (table 148).

## Special Feature: Drugs

Drugs, both prescribed and over-the-counter, are an increasingly important component of health care. New drugs, and new uses for older drugs, are improving health outcomes and quality of life, curing some conditions, preventing or delaying disease, and hastening recovery. Trends in the percent of persons who reported taking a drug during a 1-month period, as well as trends in specific types of drugs prescribed, ordered, or provided during visits to office-based physicians and hospital outpatient departments, show the extent to which large changes in practice patterns and utilization can occur during a relatively short time period.

Between 1988–94 and 1999–2000 the percent of Americans of all ages who reported using at least one prescription drug during the past month increased from 39 to 44 percent. During the same period the percent of persons who reported using three or more drugs in the past month increased from 12 to 17 percent (percents are age adjusted) (figure 26 and table 86).

In 1999–2000 more than 60 percent of adults age 45–64 years and more than 80 percent of adults age 65 years and over reported taking at least one prescription drug during the past month (figure 26 and table 86).

In 1999–2000 Mexican adults age 65 years and over were less likely to report taking a prescription drug in the past month than non-Hispanic white or non-Hispanic black adults (69 percent compared with 85–87 percent) (table 86).

Between 1995–96 and 2001–02 visits to physician offices and hospital outpatient departments in which five or more drugs were prescribed, ordered, or provided increased from 4 to 7 percent of all visits (age adjusted). This increase was largest for persons age 75 years and over, for whom the percent of visits with five or more drugs increased from 13 percent in 1995–96 to 20 percent in 2001–02 (figure 27).

The percent of civilian noninstitutionalized persons age 65 years and over with an annual out-of-pocket expense for prescribed medicine increased from 82 percent in 1987 to 88 percent in 2000. For persons age 65 years and over with prescribed medicine expenses, the average amount paid out-of-pocket increased from $321 in 1987 to $623 in 2000 (expenses in 2000 dollars) (table 120).

Between 1995–96 and 2000–01 there was a substantial increase in the rate that antidepressant drugs, blood glucose/sugar regulators, and cholesterol-lowering drugs were prescribed, ordered, or provided during visits to physician offices and hospital outpatient departments (table 87).

Among physician office visits and hospital outpatient department visits with an asthma diagnosis, the percent of visits in which a long-term control asthma drug was prescribed, ordered, or provided surpassed the percent with a quick-relief (rescue) drug between 1995–96 and 1997–98. By 2001–02, 55 percent of asthma visits had a long-term asthma control drug prescribed, ordered, or provided compared with 39 percent in 1995–96 (figure 28).

The percent of adults using antidepressants almost tripled between 1988–94 and 1999–2000. Use is higher among women than men. In 1999–2000, 10 percent of women 18 years and over reported taking an antidepressant in the past month, compared with 4 percent of men (figure 30).

In 1999–2000 the percent of non-Hispanic white adults using antidepressants was 3 times the percent among non-Hispanic black and Mexican adults. In 1988–94, use among non-Hispanic white adults was 1.4 times that among non-Hispanic black and Mexican adults (figure 31).

The rate of visits to office-based physicians and hospital outpatient departments in which a selective serotonin reuptake inhibitor (SSRI), a newer type of antidepressant, was prescribed, ordered, or provided nearly doubled between 1995–96 and 2001–02. In 2001–02 the SSRI visit rate among women was 25 visits per 100 women—more than twice the rate observed among men (figure 32).

In 2000–2002 the rate of visits with a stimulant drug prescribed, ordered or provided among boys was more than two times the visit rate among girls, reflecting the higher prevalence of identified Attention Deficit Hyperactivity Disease (ADHD) in boys compared with girls (figure 33).

The rate of visits with an antidepressant drug prescribed, ordered, or provided was similar for boys and girls in 2000–02. The antidepressant visit rate was more than twice as high among adolescents as younger school-age children (3.4 per 100 children 5–11 years of age and 8.8 per 100 adolescents 12–17 years of age) (figure 34).

For men and women age 45–64 years, the rate of drug visits to office-based physicians and hospital outpatient departments with a cholesterol-lowering statin prescribed, ordered, or provided increased by more than 200 percent between 1995–96 and 2001–02 (figure 35).

Since the introduction of selective COX-2 nonsteroidal anti-inflammatory drugs (NSAIDs), their use has become widespread. In 2001–02, selective COX-2 inhibitors accounted for 51 percent of NSAID visits among adults age 18 years and over, surpassing traditional NSAIDs. This dramatic growth in COX-2 NSAID visits is evident in all adult age groups (figure 36).