# Executive Summary

Health, United States, 2004, is the 28th annual report on the health status of the Nation and is submitted by the Secretary of the Department of Health and Human Services to the President and Congress. It assesses the Nation’s health by presenting trends and current information on selected determinants and measures of health status in a chartbook followed by 153 trend tables organized around four major subject areas: health status and determinants, health care utilization, health care resources, and health care expenditures.

Monitoring the health of the Nation is essential for identifying and prioritizing health policy, program, and research initiatives. Current measures of the health status of the population, as well as its determinants, provide critical information for assessing how the Nation’s resources should be directed to improve the health of its population. Examination of emerging trends also identifies diseases, conditions, and risk factors that warrant study and intervention. Health, United States provides an annual picture of health, and its determinants, for the entire Nation. It also identifies differences in health and health care among specific populations. Existing disparities, as well as whether any differences are narrowing or increasing, can be identified among people of differing races and ethnicities, genders, education and income levels, and geographic locations. Given the increasing diversity of the Nation and the numerous changes in the health care infrastructure over time this is a challenging task, but it is a critically important undertaking.

## Overall Health of the Nation

The health of the Nation has continued to improve overall, in part because of the resources that have been devoted to health education, public health programs, health research, and health care. The United States spends more per capita than any other country on health, and the rate of increase in spending is going up. Much of this spending is on health care—notable examples are prescription drugs and cardiac operations—that control or reduce the impact of chronic diseases and conditions affecting an increasingly older population.

Over the past 50 years many diseases have been controlled or their morbidity and mortality substantially reduced. A decline in the death rate from heart disease is an example of a major public health achievement and is in large part a result of public education campaigns emphasizing a healthy lifestyle and increased use of cholesterol-lowering medications (1). Public health and private efforts to improve motor vehicle transportation safety, as well as to increase safety in homes and workplaces, have contributed to lower death rates caused by unintentional injuries for children and adults. Finally, the decline in the death rate for HIV disease in the 1990s (table 42) demonstrates how new medical treatments can dramatically delay or decrease the number of deaths caused by a particular disease. Yet even as progress is made in improving both the quantity and quality of life, increases in longevity are associated with increased prevalence of chronic conditions. Equally important is the fact that these improvements have not been equally distributed by income, race, ethnicity, education, and geography.

### Health Status and Its Determinants

Life expectancy in the United States has shown a long-term upward trend. Infant mortality and mortality from heart disease, stroke, and unintentional injuries are all substantially lower than in 1950, contributing to the upward trend in life expectancy (figure 25 and tables 22, 29, 36, and 37). However, men and women in many other countries have longer life expectancies than in the United States. For example, in 1999 life expectancy at birth in Japan was more than 3 years longer for men and more than 4 years longer for women than in the United States (table 26).

In addition, in 2002 the infant mortality rate in the United States increased for the first time since 1958. The rise in infant mortality is attributed to an increase in neonatal deaths (infants less than 28 days old), particularly infants who died within the first week of life. However, there was a continued decrease in late-term fetal deaths—defined as 28 or more weeks of gestation (2).

Decreased cigarette smoking among adults is a prime example of a trend in a risk factor for disease and death that has contributed to declines in mortality. Even with decreases in cigarette smoking since the Surgeon General’s Report in 1964, about 25 percent of men and 20 percent of women were current smokers in 2002 (figure 12 and table 60). Overweight and obesity, and physical inactivity among both adults and children are significant risk factors for several chronic diseases, including diabetes, and these indicators have not shown improvement (table 69) (3). The rising prevalence of overweight in children and adolescents, and the high percentage of both adults and adolescents not engaging in recommended amounts of physical activity raise additional concerns for future health outcomes.

Although rates of reportable childhood infectious diseases such as mumps and measles have all but disappeared (table 51), the prevalence of many chronic diseases is increasing with the aging of the population (figure 1, table 1). In 1999–2000, more than 8 percent of persons 20 years of age and over were estimated to have diabetes, including diabetes previously diagnosed by a physician and undiagnosed diabetes based on the results of a fasting blood sugar test (table 55). Incidence rates for all cancers combined declined in the 1990s for males, although there was no significant change in cancer incidence for females overall (table 53).

Self- or proxy-reported limitation in one’s usual activities because of chronic health limitations and overall health status have not changed measurably since 1997 (tables 56 and 57). However, for persons aged 65 and over, the percentage with a limitation in one of six activities of daily living has declined since 1992 (figure 21).

### Health Care Utilization and Resources

People use health care services for many reasons—to treat illnesses and health conditions, to mend breaks and tears, to prevent or delay future health care problems, and to reduce pain and increase quality of life, as well as to obtain information about their health status and prognosis. The study of trends in health care utilization provides important information on these phenomena and spotlights areas that may warrant future in-depth studies. Trends in utilization may also be used as the basis for projecting future health care needs, health care expenditures, or manpower training or supply needs.

Use of many types of preventive or early-detection health services has been increasing. The percentage of mothers receiving prenatal care in the first trimester of pregnancy has continued to edge upward (table 6). Since 1989 the percentage of older adults ever having received a pneumococcal vaccine increased sharply (figure 10). The percentage of children 19–35 months of age vaccinated for many childhood infectious diseases is at a high level, and the percentage of children receiving the new varicella (chickenpox) vaccine has increased since 1997 (table 72). Use of Pap smears and mammograms by women in the recommended age and time intervals has also increased since 1987 (tables 81 and 82).

Admissions to hospitals and length of stay declined substantially over the 1980s and 1990s, but these declines appear to be leveling off (tables 92, 93, and 96). The diagnoses recorded on inpatient hospital stays are changing, as are the procedures being performed on inpatients (table 97). Hospitalizations for procedures that can be performed on an outpatient basis, such as lens extractions and knee arthroscopies, have all but disappeared from inpatient settings. Instead, inpatient care is becoming considerably more complex, with more procedures such as insertions of cardiac stents and hip replacements being performed, particularly on older persons (table 97). The visit rate to hospital outpatient departments is increasing for the population overall, and the number and types of services performed during visits to physicians’ offices—particularly the number of drugs prescribed, continued, administered, or provided per visit—are increasing rapidly for persons in older age groups (table 87).

As the nature of health care changes, the supply of health providers and the sites where specific services are provided have been evolving. Services that historically were provided in inpatient settings are increasingly offered in outpatient settings, and the number of physical therapy providers, comprehensive outpatient rehabilitation facilities, and ambulatory surgical centers certified by the Centers for Medicare & Medicaid Services has increased since the 1980s (table 114). The supply of some other types of providers has been declining, such as the number of inpatient mental health beds (table 110).

### Expenditures and Health Insurance

In 2002 national health care expenditures in the United States totaled $1.6 trillion, a 9.3 percent increase from 2001 (table 116). Since 1995 the average annual rate of increase for prescription drug expenditures was higher than for any other type of health expenditure (table 118), indicating the importance of prescription drugs to the Nation.

Access to health care is determined by many factors including the supply of providers and the ability to use and pay for available care. Health insurance is strongly associated with the ability to access health care services and providers. The percentage of the population under 65 years of age with no health insurance coverage (either public or private) fluctuated around 16–17 percent between 1994 and 2002 (figure 7 and table 131). In 2002 the percentage with private health insurance decreased (figure 6 and table 132). This decrease was offset by an increase in the percentage with Medicaid, resulting in little change in the percentage uninsured.

### Disparities in Risk Factors, Access, and Utilization

Throughout the 21st century, efforts to improve health will be shaped by important changes in the U.S. population. Efforts to improve health care will be in the context of a Nation that is growing older and becoming more racially and ethnically diverse. In 2001 more than one-quarter of adults and one-third of children were identified as black, Hispanic, Asian or Pacific Islander, or American Indian or Alaska Native. Thirteen percent of the U.S. population identified themselves as Hispanic, and 4 percent as Asian or Pacific Islander (table 1).

Health, United States, 2004, identifies major areas where disparities in health and health care exist by race, ethnicity, and socioeconomic status. Persons living in poverty are considerably more likely to be in poor health and less likely than nonpoor persons to have used many types of health care. In 2002 the percentage of persons reporting their health status as fair or poor was more than three times as high for persons living below the poverty level as for those with family income more than twice the poverty level (table 57). Poor persons were four times as likely as nonpoor persons to report serious psychological distress (table 58).

Large disparities in infant mortality rates remain among racial and ethnic groups (table 19), and the gap in life expectancy between the sexes and between the black and white populations has been narrowing, but persists (table 27). Disparities in access to health care, risk factors, and morbidity also persist among persons under 65 years of age of Hispanic origin, and American Indians who are more likely to be uninsured than are those in other racial and ethnic groups. Obesity, a major risk factor for many chronic diseases, also varies by race (figure 17 and tables 69 and 70). Diabetes, which is associated with obesity, rises sharply with age and is more common among non-Hispanic black and Mexican persons than non-Hispanic white persons (table 55). While many aspects of the health of the Nation have improved as a whole, the health of some subpopulations has lagged behind. The large differences in health status by race and Hispanic origin documented in this report may be explained by several factors including socioeconomic status, health practices, psychosocial stress and resources, environmental exposures, discrimination, and access to health care (4). Socioeconomic and cultural differences among racial and ethnic groups in the United States will likely continue to influence patterns of disease, disability, and health care use in the future.

## Special Feature: Drugs

Drugs are defined as articles intended for use in the diagnosis, cure, mitigation, treatment, or prevention of disease or nonfood articles intended to affect the structure or any function of the body of man or other animals (5). Drugs, both prescribed and nonprescription, are an increasingly important component of health care. They can cure some diseases (e.g., antibiotics); control symptoms (e.g., analgesics or pain relievers and asthma drugs); replace or supplement needed chemicals (e.g., insulin and vitamins); and control the body’s self-regulating systems (e.g., high blood pressure and thyroid drugs). Drugs can serve as complements to medical procedures (e.g., anticoagulants during heart valve replacement surgery); deterrents to disease and disability (e.g., lipid-lowering drugs that lessen the risk of coronary artery disease); and new treatments where previously there were none (e.g., drugs for HIV). Factors affecting the recent increase in utilization of medications include the growth of third-party insurance coverage for drugs, the availability of successful new drugs, marketing to physicians and increasingly directly to consumers, and clinical guidelines recommending increased utilization of medications for conditions such as high cholesterol, acid-reflux disease, and asthma (6,7).

Between 1988–94 and 1999–2000 the percentage of noninstitutionalized Americans of all ages who reported using any prescription drug during the past month increased from 39 to 44 percent (age adjusted) (figure 26 and table 86). During the same period the percentage of persons who reported using three or more drugs in the past month increased from 12 percent to more than 17 percent (age adjusted) (figure 26 and table 86). Perhaps most striking is the increase in the percentage of older persons who reported taking three or more prescription drugs during a 1-month period—almost one-half of those 65 and over in 1999–2000, compared with just over one-third in 1988–94. Use of drugs for some conditions is increasing (e.g., cholesterol-lowering statin drugs and antidepressant drugs) (figures 30–36). For other conditions, such as asthma, some classes of drugs appear to be replacing older drugs (figures 28 and 29).

Trends in drug use illustrate how practice patterns and health care are changing over time. Drugs can increase both length and quality of life, particularly for older persons, but they also incur costs and may have damaging side effects and interactions. As the use of multiple drugs increases and drug expenditures continue to rise, tradeoffs between drugs’ costs and benefits are becoming major clinical and policy issues.

Continued collection and dissemination of reliable and accurate information about all components of health, its determinants, and resources expended will be critical for charting future trends, identifying how resources can be most effectively targeted, and prioritizing and evaluating programs and policies that will improve the health of all Americans. Following are highlights from Health, United States, 2004 With Chartbook on Trends in the Health of Americans that summarize major findings.

## References

1 Achievements in Public Health, 1900–1999: Decline in deaths from heart disease and stroke—United States, 1900–1999. MMWR 48(30):649–56. 1999.
2 Kochanek KD, Martin JA. Supplemental analyses of recent trends in infant mortality. Centers for Disease Control and Prevention, National Center for Health Statistics. Accessed on May 10, 2004, at www.cdc.gov/nchs/products/pubs/pubd/hestats/infantmort/infantmort.htm.
3 Flegal KM, Carroll MD, Ogden CL, et al. (2002). Prevalence and trends in obesity among US adults, 1999–2000. JAMA.
4 Williams DR, Rucker TD. (2000). Understanding and addressing racial disparities in health care. Health Care Financ Rev.
5 The Food, Drug and Cosmetic (FD&C) Act, sec. 201(g)(1).
6 Berndt ER. (2001). The U.S. pharmaceutical industry: Why major growth in times of cost containment?. Health Affairs.
7 Chockley N. The emerging impact of direct-to consumer prescription drug advertising. Testimony before the Subcommittee on Consumer Affairs, Foreign Commerce and Tourism of the Senate Committee on Commerce, Science and Transportation. July 24, 2001.